# METHODS

## TOPIC DEVELOPMENT

The Veterans Health Administration (VHA) uses quality improvement strategies, including clinical practice guidelines, clinical reminders in the electronic medical record, and performance measurement to improve care processes. For veterans with depression and other mental illnesses managed in primary care settings, the VHA has recently made major investments in integrated primary care-mental health programs. This project was nominated by Ira Katz, Deputy Chief, Patient Care Services for Mental Health, and Carla Cassidy and Joe Francis, Office of Quality and Performance, with input from a technical expert panel. The overall goal was to synthesize data on the efficacy of psychotherapy in patients who do not fully remit with adequate antidepressant treatment.

Therefore, the key question was as follows:

- In primary care patients with major depressive disorder who do not achieve remission with acute phase antidepressant treatment, is empirically based psychotherapy used as an augmentation or substitution treatment more effective than control for achieving remission?

For the purposes of this review, cognitive therapy (CT), interpersonal therapy (IPT), problem-solving therapy, dialectical behavior therapy (DBT), acceptance and commitment therapy (ACT), and mindfulness based cognitive therapy (MBCT) were considered as empirically based psychotherapies.

## SEARCH STRATEGY

We searched PubMed between 1950 and February 26, 2009 using standard search terms. Appendix A provides details of the search terms. Our strategy was twofold. First, we attempted to identify a good quality, relevant systematic review that would summarize the extant literature. If identified, our strategy would be to search for randomized clinical trials since the original review. No such systematic review was identified. Consequently, we searched PubMed for relevant randomized clinical trials (RCT). Titles, abstracts and full text articles were reviewed in duplicate. Data were extracted in duplicate from articles meeting all inclusion criteria. We then rated the overall quality of each study, assigned a grade, and summarized the data in narrative. Eligible articles were imported into an electronic reference database (EndNote^®^ XI).

## STUDY SELECTION

Two trained researchers independently reviewed the titles and/or abstracts of citations identified through the PubMed literature search. If articles did not clearly meet the inclusion criteria, they were excluded at the title and abstract level. The remaining articles were identified for full text review, at which stage those that did not meet inclusion criteria were excluded. In case of disagreement, the two reviewers met to identify and resolve the disagreement. To be eligible, the articles had to be published in English, and include:

- English-speaking adult outpatients from general medical settings.
- Randomized clinical trial involving at least one of the following psychotherapy modalities: cognitive behavior therapy (CBT), interpersonal therapy (IPT), problem-solving therapy, dialectical behavior therapy (DBT), acceptance and commitment therapy (ACT), or mindfulness based cognitive therapy (MBCT).
- Patients with resistant MDD, defined as a sample consisting of at least 80% with either no remission or partial remission after being treated with adequate dose of an antidepressant for at least six weeks.
- Articles were excluded if patients were receiving psychotherapy at the time of recruitment, and/or if patients had comorbid psychiatric conditions that required specialty psychiatric care. These included, but were not limited to, active suicidal or parasuicidal ideation, severe substance abuse, or borderline personality disorder.

## DATA ABSTRACTION

The following data were abstracted on the included studies: definition of persistence; type of psychotherapy; type of comparison group; setting (primary care/mental health clinic); VA (Yes/No); sample size; study-specific inclusion/exclusion criteria; age/sex/race of sample; indices of MDD severity (duration of current episode; number of prior episodes; number of hospitalizations; number of suicide attempts); data on interviewer-rated depression severity (if applicable); data on self-reported depression severity (if applicable); duration of follow-up. All data were abstracted by one reviewer with oversight being provided by the other reviewer. All disagreements were resolved using discussion and consensus.

## QUALITY ASSESSMENT

Quality of selected articles was assessed using the quality rating tool described in Appendix C. We abstracted data on completeness of follow-up (<30% drop-out rate, <10% differential dropout rate); method to address incomplete data; adequacy of randomization; adequacy of allocation concealment; outcome assessment blind to intervention allocation; and whether there was a conflict of interest, either stated or implied.

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included articles, organized by the unique studies from which they were derived. We critically analyzed studies to compare characteristics, methods, and findings. We compiled a summary of findings and drew conclusions based on qualitative synthesis of the findings.

## PEER REVIEW

A draft version of this report was sent to three peer reviewers. Their comments and our responses are presented in Appendix B.