# FUTURE RESEARCH

There is a pressing need to conduct RCTs examining psychotherapy as a second step treatment in patients who have not responded to initial antidepressant medication treatment. Studies conducted within the VA would provide the best evidence on how to treat veterans. As more OEF/OIF veterans return with significant medical and psychiatric comorbidities, this question will become critical in the management of MDD.

Future investigations should also address cost-effectiveness of the different treatment options. To our knowledge, no current study has examined the cost-effectiveness of psychotherapy versus antidepressant treatment when used as second step treatment. As a first step, analyses using observational data from the VA depression registry may be informative. Ideally, however, studies designed for this purpose would involve longer follow-up, as well as measures of direct costs, indirect costs, and costs associated with comorbid non-psychiatric conditions. Finally, innovative interventions are needed that adapt validated psychotherapeutic techniques to primary care settings. The VA has already initiated primary care mental health integration techniques; however, there remains a need for trials of depression treatments to inform the specific treatments offered in these integrated models. This will be crucial in improving access for underserved veterans while simultaneously reducing the strain on the VA resources.