# EVIDENCE REPORT

## INTRODUCTION

Major depressive disorder (MDD) is one of the leading causes of disability worldwide. 1 The lifetime prevalence of MDD in the general population is estimated at 13%^2^, of which approximately 20% will experience chronic depression and 60–85% will experience recurrence and relapse.3 This number is even higher in the VA medical system, where an estimated one third of veterans experience MDD.4 MDD is associated with greater health care utilization, greater functional impairment, and increased mortality.2 In addition, subclinical symptoms of depression can reduce quality of life, worsen disability, and adversely affect co-existing chronic medical conditions.5–8 Both antidepressant medications and depression-specific psychotherapies are effective as first-line treatments for MDD. In primary care settings, most patients with MDD are treated with antidepressant medications, but a substantial proportion of patients fail to recover with this initial treatment. This evidence synthesis was requested to evaluate the efficacy of psychological treatments as step-2 treatment for patients with MDD who do not achieve remission with an initial course of antidepressant medication.

## BACKGROUND

Antidepressant medications are the most commonly prescribed treatment modality in MDD.9 The most recent American Psychiatric Association (APA) guidelines10 suggest the use of antidepressants for mild, moderate or severe depressive disorders, a position that has remained consistent in the more recent “guideline watch” by Fochtmann & Gelenberg (2008).11 The efficacy and effectiveness of antidepressant treatment in primary care have been demonstrated in multiple large scale studies and systematic reviews.12–16 Several classes and types of antidepressants exist which do not substantially differ in their efficacy or effectiveness for treating MDD.17 Therefore, primary care physicians have a wide array of antidepressant options that they may prescribe depending on suitability to patient, patient preference, affordability, side effect profile, and the targeted physiological system. 17

In addition, a sizeable body of literature has examined the efficacy and effectiveness of psychotherapy as acute phase treatment for MDD, either as monotherapy or in combination with antidepressant treatment. Psychotherapy is a heterogeneous class of treatments in which the therapist utilizes interpersonal strategies with the intention of alleviating mental or emotion distress.18 Cognitive therapy (CT) is the most widely studied form of psychotherapy for depression, although many other psychotherapeutic modalities exist that are depression-specific, empirically validated, and accessible through referral or adoption by the primary care team. Recent reviews and meta-analyses of acute phase treatment for depression have shown that psychotherapy may be as effective as antidepressant treatment and more effective than usual care in treating mild, moderate, and severe MDD.19–23 When MDD is severe, chronic or recurrent, the combination of medication and psychotherapy as initial treatment appears to be indicated.17 Combination of psychotherapy with an antidepressant has demonstrated greater treatment gains, lower relapse rates, and increased adherence to treatment when compared to usual care or antidepressant monotherapy.24–27 Therefore, current evidence suggests that antidepressants and psychotherapy may both form effective first line treatments in patients with MDD, individually or in combination.

However, response to initial treatment for MDD remains poor even when treatment recommendations are rigorously followed.28, 29 Fewer than 50% of patients fully remit after an adequate trial of antidepressant medication or psychotherapy.30, 31 Patients who do not fully remit are often considered “treatment resistant” or “treatment refractory.” Treatment resistant depression (TRD) is typically defined as an inadequate response to at least one 6-week or longer trial of an antidepressant at an adequate dose.32 TRD does not include patients who did not adhere to initial treatment recommendations. Clinical factors associated with treatment resistant depression (TRD) include comorbid generalized anxiety and other Axis I disorders (e.g., phobias), early onset of MDD, previous suicide attempts, number of prior depressive episodes, older age, and unemployment.33–36 In primary care settings, these findings may help physiciansa priori determine patients who may be most at-risk for TRD.

Primary care physicians have several options when treating patients with TRD: augmenting treatment by adding another medication; switching to a different antidepressant; augmenting treatment through adding psychotherapy; and switching from medication to psychotherapy.37 However, studies of clinical practice suggest that medications are often the only active treatment provided by primary care providers as a second step treatment for MDD.17, 38 Several limitations to this approach should be noted. First, the addition of another antidepressant may increase the number and/or severity of side effects that patients experience. Side effects are known to reduce quality of life and increase the chances of non-adherence, interfering with the treatment of MDD.39 Second, focus on antidepressants may ignore the potential impact of psychosocial factors in TRD. For instance, cognitions and behaviors related to MDD may be interfering with the treatment regimen and may best be modified by skills training. This is especially true when patients are experiencing acute stressors (e.g., bereavement), where psychotherapy may improve patients’ long-term outcomes.23 Third, patients may simply not respond to antidepressant treatment or may not prefer taking medications. In all of these scenarios, the addition or substitution of psychotherapy may be a preferred alternative.

In summary, psychotherapy and pharmacotherapy appear to be equally effective as initial approaches to treating MDD in primary care. However, approximately half of patients do not remit after initial treatment even when treatment regimens are rigorously followed. Switching to a different antidepressant or augmenting treatment by adding a second antidepressant medication are both common clinical practices that are recommended in current guidelines as second step treatment strategies. However, the addition or substitution of psychotherapy is not addressed as a step-2 treatment for MDD in published guidelines.

Therefore, the focus of the current review is two-fold:

- To review literature examining the use of psychotherapy as a second line treatment for patients with depression who do not remit with initial antidepressant medication; and,
- To determine the applicability of these studies to VA patients treated in primary care settings.

The purpose of this review was to generate guidelines that would help determine whether the use of psychotherapy, either as an augmentation or a switch strategy, would lead to better outcomes in patients who had not responded to initial adequate antidepressant treatment.