# EVIDENCE TABLES OF RCTS

Study ID | Persistence Definition & Treatments | Study Information | Participants | Results | Comments/Quality Scoring
Harley et al., 2008 | Persistent Depression: Despite stable, adequate medication treatment for MDD (as determined by consensus of 2 senior psychiatrists with expertise in MDD), patients still met criteria for MDD on the SCID-I. Psychotherapy: [underlined: Dialectical Behavior Therapy (DBT) Group] DBT based depression skills group; 16 weekly sessions lasting 90 minutes each. Comparator: [underlined: Wait List (WL)] Pts in this group continued treatment as usual, which included taking prescribed medications and meeting with psychiatrists and other providers as usual. | Geographical location: Boston, MA Setting: MHC; participants were referred by outpatient providers. VA sites: No Study design: RCT Number of participants enrolled: Total: 24 DBT: 13 WL: 11 Duration of follow up: 16 weeks Inclusion criteria: - Age 18–65 - Principal diagnosis of MDD on SCID - Have an established treatment relationship with a psychiatrist - Stabilized on adequate dose of antidepressant medication before entering study (no dosage change for at least 6 weeks before study entry) Exclusion criteria: - Bipolar disorder - Psychotic spectrum disorders - Active substance abuse or dependence - Mental retardation - Pervasive developmental disorder - Active suicidality - Severe or unstable medical conditions - Patients with previous or current CBT experience - Borderline Personality Disorder | Age: [mean] Total: 41.8 Sex: [female %] Total: 75% Race/ethnicity: [white (%)] Total: 83% Duration of current episode in days: [mean (SD)] DBT: 201.00 (131.59) WL: 292.40 (374.94) Number of lifetime antidepressant trials: [mean (SD)] DBT: 3.31 (1.70) WL: 4.27 (2.45) Number of hospitalizations: [mean (SD)] DBT: 0.85 (0.99) WL: 0.27 (0.65) Age at first MDE: [mean (SD)] DBT: 27.08 (14.23) WL: 25.18 (15.20) Engaged in concurrent non-CBT individual therapy: Total: 83% | 1) Interviewer rated depression severity: HAM-D at baseline: [mean (SD)] DBT: 16.15 (4.47) WL: 18.64 (4.72) HAM-D at follow-up: [mean (SD)] DBT: 11.30 (5.31) WL: 17.11 (6.23) DBT group had significantly lower HAM-D scores than WL (F=4.63; p<.05; D=1.45). 2) Self-reported depression severity: BDI at baseline: [mean (SD)] DBT: 27.31 (8.83) WL: 27.44 (11.66) BDI at follow-up: [mean (SD)] DBT: 15.10 (12.13) WL: 25.89 (16.30) DBT group had significantly lower BDI scores than WL (F=9.50; p<.01; D=1.31). | Comments: Small sample sizes, limited information provided on samples’ baseline characteristics, and confound of individual therapy. Quality assessment: Randomization adequate?: Y Allocation concealment adequate?: Y Baseline comparability?: Y Valid outcome assessment?: Y Subject/providers blind?: N Outcomes assessed blind?: Y Dropout rate < 30%?: Y Differential dropout rate < 10%?: Y Incomplete data addressed adequately?: Unknown Conflict of interest?: N Overall quality rating: Fair
Kennedy et al., 2003 | Persistent depression: Having initially met criteria for MDE with HAM-D-17≥16 and after 8–14 weeks of antidepressant treatment with moclobemide (300–600 mg/day), paroxetine (20–40 mg/day), sertraline (50–200 mg/day), or venlafaxine (75–225 mg/day), patients still had HAM-D=8–15. Psychotherapy: [underlined: Cognitive Therapy (CT)] 12 sessions over 8 weeks in combination with AD therapy; pts were also seen every 4 weeks for a medication check up. Comparator: [underlined: Lithium Augmentation (LA)] Pts who were considered “partial responders” had their AD therapy augmented with 600 mg/day of lithium carbonate, which clinicians could increase by 300 mg/day after 2–4 weeks. Pts were seen every 2 weeks for routine clinical management. | Geographical location: Toronto, Canada Setting: MHC VA sites: No Study design: RCT Number of participants enrolled: Total: 44 CT: 23 LA: 21 Duration of follow up: 8 weeks Inclusion criteria: - Age 18–65 - Partial response after receiving maximum tolerated doses of moclobemide, paroxetine, sertraline, or venlafaxine (choice of antidepressant was at the discretion of the treating psychiatrist) for 8–14 weeks - Initially met criteria for MDE - HAM-D-17≥16 - At least one prior MDE Exclusion criteria: - Major medical disorder - Organic brain syndrome - Schizophrenia or schizoaffective disorder - Bipolar disorder - MDD with psychotic features - Substance or alcohol use or dependence within past 6 months | Age: [mean (SD)] CT: 40.7 (12.5) LA: 37.7 (11.3) Sex: [female, n (%)] CT: 12 (52.2%) LA: 12 (57%) Race/ethnicity: Not reported Duration of current episode in weeks: [mean (SD)] CT: 126.4 (170.4) LA: 119.8 (160.8) Number of prior episodes: [mean (SD)] CT: 2.1 (1.5) LA: 2.3 (1.4) Age at first MDE: [mean (SD)] CT: 26.3 (13.5) LA: 24.4 (13.6) Comorbid psychiatric diagnoses: [n (%)] CT: 8 (35%) LA: 4 (19%) | 1) Interviewer rated depression severity: HAM-D-17 after 8–14 weeks med treatment: [mean (SD)] CT: 12.1 (2.2) LA: 11.6 (1.9) HAM-D-17 at follow-up: [mean (SD)] CT: 14.8 (9.9) LA: 9.2 (6.7) LA group had significantly lower HAM-D-17 scores than CT group in intent-to-treat analysis (t=2.02; df=42; p=.04; d=.32). 2) Self-reported depression severity: BDI after 8–14 weeks med treatment: [mean (SD)] CT: 22.7 (8.6) LA: 22.4 (10.3) BDI at follow-up: [mean (SD)] CT: 19.9 (10.3) LA: 15.1 (11.4) No significant differences between groups. | Comments: Only included partial responders; excluded non-responders. Quality assessment: Randomization adequate?: Y Allocation concealment adequate?: Y Baseline comparability?: Y Valid outcome assessment?: Y Subject/providers blind?: N Outcomes assessed blind?: Y Dropout rate < 30%?: Y Differential dropout rate < 10%?: Y Incomplete data addressed adequately?: Y Conflict of interest?: N Overall quality rating: Good
Paykel et al., 1999 Paykel et al., 2005 Scott et al., 2003 Scott et al., 2000* Teasdale et al., 2001 *Data were primarily extracted from this reference. | Persistent depression: Despite treatment with tricyclic antidepressant, SSRI, atypical AD, or MAOI for at least 8 weeks (with 4 or more weeks of minimum dosage equivalent to at least 125 mg of amitriptyline), patients still had HAM-D ≥8 & BDI ≥9. Psychotherapy: [underlined: Cognitive Therapy (CT)] 16 sessions over 20 weeks. Pts also received CM. Comparator: [underlined: Clinical Management (CM)] Antidepressant continuation; pts seen every 4 weeks during tx and every 8 weeks during follow-up for 30 minutes each. | Geographical location: Cambridge & Newcastle, England Setting: MHC; Psychiatric Outpatient Clinics VA sites: No Study design: RCT Number of participants enrolled: Total: 158 CT: 80 CMT: 78 Duration of follow up: 20 weeks Inclusion criteria: - Age 21–65 - DSM-III-R MDD within past 18 months but not MDD criteria in past 2 months & HRSD ≥ 8 & BDI ≥ 9. Exclusion criteria: - Bipolar disorder - Cyclothymia - Schizoaffective disorder - Drug or alcohol dependence - Antisocial behavior or self-harm - Dysthymia before age 20 - Borderline personality - Learning disability - Organic brain damage - Other primary Axis I disorder - Currently receiving psychotherapy or previously received CT for more than 5 sessions | Age: [mean (SD)] CT: 43.5 (9.8) CM: 43.2 (11.2) Sex: [female, n (%)] CT: 37 (46%) CM: 41 (53%) Race/ethnicity: Not reported Duration of depressive episode in months: [median (1^st^ & 3^rd^ quartiles)] CT: 14.5 (9, 18) CTM: 13 (9, 21) Prior episodes of MDD: [median (1^st^ & 3^rd^ quartiles)] CT: 2 (1, ≥ 3) CM: 2 (1, ≥ 3) | 1) Interviewer rated depression severity: HDRS baseline after 8 week drug trial: [mean (SD)] CT=12.1 (2.7) CM=12.2 (2.9) HDRS at follow-up: [mean (SD)] CT=8.7 (5.3) CM=9.4 (5.3) No significant between group differences or group x time interactions over 20 week treatment phase or 68 week follow-up (F=2.2; df=1324; p=.14) 2) Self-reported depression severity: BDI baseline after 8 week drug trial: [mean (SD)] CT=21.7 (7.7) CM= 22.3 (8.0) BDI at follow-up: [mean (SD)] CT=13.8 (9.6) CM= 16.1 (10.0) No significant between group differences or group x time interactions over 20 week treatment phase or 68 week follow-up (F=2.3; df=1293; p=.13) | Comments: Not currently depressed; partially remitted but with residual symptoms - because not MDD but still some depressive symptoms on HDRS and BDI In Scott et al. 2000, found that some dep sx showed sig effects on drug refractory residual symptoms Both CT and CM led to improvement in dep sx Quality assessment: Randomization adequate?: Y Allocation concealment adequate?: Y Baseline comparability?: Y Valid outcome assessment?: Y Subject/providers blind?: N/Y Outcomes assessed blind?: Y Dropout rate < 30%?: Y Differential dropout rate < 10%?: Y Incomplete data addressed adequately?: Y Conflict of interest?: N Overall quality rating: Good
Rush et al., 2004 Rush et al., 2006 Thase et al., 2007* Wisniewski et al., 2007 STAR*D *Data were primarily extracted from this reference. | Persistent depression: Following treatment with citalopram (20 mg/day to start, 40 mg/day by week 4, and maximum potential dosage of 60 mg/day by week 6) for 14 weeks, patients still had HAM-D≥14. Psychotherapy: [underlined: Cognitive Therapy (CT)] 16 sessions delivered twice weekly for weeks 1–4, then once weekly for 8 remaining weeks. Switch to CT: Pts discontinued citalopram and began CT. Augment CT: Pts continued on citalopram and added CT. Comparator: [underlined: Antidepressant Medication (ADM)] Switch ADM: Pts discontinued citalopram and began bupropion, sertraline, or venlafaxine. Augment ADM: Pts continued on citalopram and added bupropion or buspirone. | Geographical location: 14 Regional centers across TX, MA, NY, PA, OK, KS, CA: LA and San Diego, NC, IL, MI, VA, TN, AL Setting: 18-Primary Care, 23 MHC VA sites: No Study design: randomized multi-step clinical trial Number of participants enrolled: Total: 304 Switch to CT=36 Augment CT=65 Switch ADM=86 Augment ADM=117 Duration of follow up: 14 weeks Inclusion criteria: - Age 18–75 - Non psychotic MDD - HRSD17≥14 Exclusion criteria: - Bipolar, schizophrenia, eating d/o, OCD - Hx of intolerability or resistance to ≥ 1 Anti-dep with adequate dosage - ≥ 7 days Citalopram use prior to study enrollment - non-responsive ≥ 16 session of CT in current MDD episode - Medical contraindication - Pregnant females - Requires psychiatric hospitalization, antipsychotics, or mood stabilizers | Age: [mean (SD)] Switch to CT: 43.4 (14.7) Augment CT= 40.6 (11.5) Switch ADM=41.5 (13.3) Augment ADM=39.7 (13.5) Sex: [female, n (%)] Switch to CT: 22 (61.1%) Augment CT: 41 (63.1%) Switch ADM: 53 (61.6%) Augment ADM: 78 (66.7%) Race/ethnicity: [white, n (%)] Switch to CT: 28 (77.8%) Augment CT: 52 (80.0%) Switch ADM: 63 (73.3%) Augment ADM: 99 (84.6%) Duration of depressive episode in months: [mean (SD)] Switch to CT: 17.4 (31.2) Augment CT: 29.6 (49.4) Switch ADM: 26.5 (54.0) Augment ADM: 20.0 (47.5) Number of prior episodes of MDD: [mean (SD)] Switch to CT: 8.7 (18.8) Augment CT: 7.3 (14.1) Switch ADM: 8.4 (16.0) Augment ADM: 4.6 (5.4) | 1) Interviewer rated depression severity: HRSD at start of Level 2: [mean (SD)] Switch to CT: 16.4 (6.2) Augment CT: 17.8 (5.7) Switch ADM: 17.7 (6.6) Augment ADM: 16.0 (6.7) Met remission criteria on (HRSD≤7) at end of Level 2: Switch to CT: 25.0% Augment CT: 23.1% Switch ADM: 27.9% Augment ADM: 33.3% No significant differences between groups. 2) Self-reported depression severity: QIDS-C at start of Level 2: [mean (SD)] Switch to CT: 11.2 (4.3) Augment CT: 11.9 (4.3) Switch ADM: 12.1 (4.6) Augment ADM: 12.0 (4.6) QIDS-C at end of Level 2: [mean (SD)] Switch to CT: 9.1 (5.4) Augment CT: 8.2 (5.1) Switch ADM: 9.1 (5.0) Augment ADM: 8.2 (4.8) No significant differences between groups. | Comments: Due to equipoise-stratified randomization, <1/3 agreed to randomization. Low rates of psychotherapy acceptability are at odds with real world experience of the STAR*D authors. Baseline differences in Augment CT more impaired & lower QOL than Augment ADM and Switch to CT lower income than Switch ADM. Numerous pharmaceutical companies supported the project. Quality assessment: Randomization adequate?: Y/N Allocation concealment adequate?: Y Baseline comparability?: Y/N Valid outcome assessment?: Y Subject/providers blind?: N Outcomes assessed blind?: Y Dropout rate < 30%?: Y Differential dropout rate < 10%?: Y Incomplete data addressed adequately?: Y Conflict of interest?: Y Overall quality rating: Good
Blackburn & Moore, 1997 | Persistent depression: Despite showing significant reduction in depressive symptoms over 16 weeks of treatment with antidepressant medication of the general practitioner’s choice (prescribed at or above therapeutic doses), patients on average continued to have depressive symptoms in the moderate range on the BDI and above the traditional cut point of 11 on the HAM-D. Psychotherapy: [underlined: Cognitive Therapy (CT)] 27 sessions delivered over 2 years, with pts being seen 3 times in 1^st^ month, twice in 2^nd^ month, and monthly thereafter. Comparator: [underlined: Antidepressant Medication (ADM)] Maintenance ADM was of general practitioner’s choice (tricyclics, MAOIs, SSRIs), as long as prescribed at or above recognized maintenance dose. | Geographical location: Scotland Setting: MHC; participants were recruited from outpatient referrals to consultants in a large teaching psychiatric hospital and from 2 general practices. VA sites: No Study design: RCT Number of participants enrolled: Total: 37 (48 initially) CT: 17 (22 initially) ADM: 20 (26 initially) Duration of follow up: 24 months Inclusion criteria: - Age 18–65 - Diagnosis of primary major unipolar depression, non-psychotic - Score of at least 16 on HRSD - Current episode had to be at least second MDE Exclusion criteria: - Having another primary Axis I disorder - Organic brain damage - History of bipolar illness - Alcohol or drug misuse - Could not be prescribed antidepressant medication for medical reasons - Unwilling to be randomly allocated to treatment | Age: [mean (SD)] CT: 37.8 (13.1) ADM: 40.1 (12.7) Sex: [female, n (%)] CT: 17/22 (77%) ADM: 17/26 (65%) Race/ethnicity: Not given Duration of current episode in months: [mean (SD)] CT: 7.0 (1.4) ADM: 6.9 (1.3) Number of prior episodes: [mean (SD)] CT: 4.1 (3.4) ADM: 3.2 (2.2) Number of hospitalizations: [mean (SD)] CT: 0.7 (0.9) ADM: 0.8 (2.3) Number of suicide attempts: [mean (SD)] CT: 0.4 (0.7) ADM: 0.9 (1.9) *Data based on initially enrolled participants. | 1) Interviewer rated depression severity: HRSD baseline after 16 weeks acute med treatment: [mean (SD)] CT: 11.8 (6.3) ADM: 10.6 (6.8) HRSD interpolated over 24 months follow-up: [mean (SD)] CT: 8.6 (5.6) ADM: 9.3 (7.2) ANCOVA showed no significant difference between treatments (F=0.31; d.f.=2, 55; NS). 2) Self-reported depression severity: BDI baseline after 16 weeks acute med treatment: [mean (SD)] CT: 20.4 (11.1) ADM: 19.7 (14.2) BDI interpolated over 24 months follow-up: [mean (SD)] CT: 14.2 (9.9) ADM: 18.1 (13.1) ANCOVA showed no significant difference between treatments (F=0.72; d.f.=2, 53; NS). | Comments: Reviewers decided based on data after 16 weeks of treatment that samples met criteria for persistent depression. ANCOVAs compared 3 groups, not just the 2 groups of interest. 35% retention for CT and 25% retention for ADM. Quality assessment: Randomization adequate?: Y Allocation concealment adequate?: Y Baseline comparability?: Y Valid outcome assessment?: Y Subject/providers blind?: N Outcomes assessed blind?: Y Dropout rate < 30%?: N Differential dropout rate < 10%?: N Incomplete data addressed adequately?: Y Conflict of interest?: N Overall quality rating: Poor