# PEER REVIEW

Question 1: Are the objectives, scope, and methods for this review clearly described?
Reviewer | Comment | Reply
1 | Excellent description of objectives, scope, and methods. This review exposes the scarcity of good studies to answer this question. The conclusions fit the data. | Acknowledged
2 | Clearly described, concisely written, comprehensive, well thought out review. | Acknowledged
3 | The authors have been particularly thorough in describing clearly the objectives, scope, and methods for this review. I don’t believe any reader would be left with any question about these. | Acknowledged
3 | (As a small matter, on page 15, “solution-focused therapy” was listed as one of the empirically-based psychotherapies that were considered for purposes of the study. However, in Appendix A, this was not listed as one of the search terms; “problem-solving” was listed. I think these are both terms of art, and are different. Do you want to conform the terms? I think the authors likely considered problem solving therapy, but not solution-focused therapy.) | Thank you for pointing out this discrepancy. We have now changed the term “solution-focused therapy” to “problem-solving therapy” to reflect terms included in the literature search (pg 15, 16).
Question 2: Is there any indication of bias in our synthesis of the evidence?
Reviewer | Comment | Reply
1 | No indication of bias. This review follows rigorous methods for systematic selection and analysis | Acknowledged
2 | No | Acknowledged
3 | I see no indication of bias in the synthesis of the evidence. Indeed, it appears that the authors have gone out of their way to eliminate any opportunity for bias. | Acknowledged
Question 3 Are there any studies on responsiveness of depression questionnaires or relapse prevention trials related to this report that we have overlooked?
Reviewer | Comment | Reply
1 | I don’t know of any others | Acknowledged
2 | None | Acknowledged
3 | I don’t know of any studies on the effectiveness of psychotherapy as a second step treatment for MDD in patients who do not achieve remission after initial treatment with antidepressants, per se, that have been overlooked. | Acknowledged
Question 4: Please write additional suggestions or additional comments below for this report. If applicable, please indicate the page and line numbers from the draft report.
Reviewer | Comment | Reply
1 | P 6, last line: suggest changing “control” to “comparison group,” a term that is more consistent with most patients in this group being on some form of treatment. This review achieves impressive rigor and thoroughness for such a limited number of studies. | We agree with this assertion and have attempted to make this point throughout the review. However, in that specific place, we have opted to retain the wording as initially developed by VA Central Office to avoid confusion regarding the question we were originally attempting to answer with this review.
2 | 4.
2 | a. p. 9 typo, 2^nd^ line from bottom: should be “antidepressant medication with CT. | a. Thank you for finding this error. The typo has been corrected.
2 | b. p.10 I think the summary and conclusions understate the equivalence of CT vs medication as a switch choice. The STAR*D data suggested little difference for the between CT and meds for the switch arms, and hence for patients who would prefer CT it may be a reasonable option. c. I’m concerned with the statement: “Based on this sparse evidence, we conclude that current trials do not support a benefit from adding psychotherapy to antidepressant medication for mid-life adults with treatment resistant MDD”. While it is technically correct, I think it is at risk of being mis-interpreted too strongly as an indication that there is no role for CT as an adjunct in TRD. It seems the evidence is insufficient to conclude one way or the other, and I think the wording should reflect that the current data do not support a benefit, but that the data is insufficient to make a conclusion and that future studies may likely change this result. | b.& c. We agree with the reviewer that our summary and conclusions did not emphasize the equivalence of the two treatment modalities. We have modified the summary statements on pages 9, 10, and 30 to reflect the equivalence that we generally observed in studies comparing CT and meds, and to reflect our belief that CT remains a reasonable treatment option in patients with TRD. As we state repeatedly in the review, the current evidence is not sufficient to determine the superiority of one treatment modality over the other. Future research with rigorous study designs is necessary to definitively answer this question.
2 | d. p.20. Table 1 might benefit from a row that allows a better comparison of the level of depressive severity when beginning psychotherapy treatment, for e.g., clarifying the BDI or QIDS scores as “mild”, “moderate” or “severe”, and a row that allows comparison of the prior antidepressant treatment (e.g., antidepressant type, dose, duration). Also, can one report the number of prior treatment failures for the current episode? Finally, the definition of persistent depression (listed in the evidence tables in the appendices) is quite information and would be a useful row in Table 1. I realize, however, that some of this information may not be available for many studies. | d. Per the reviewer’s suggestion, we report that that depression severity in each study was “moderate.” We agree with the reviewer that the number of failures of treatment may be important information in evaluating the extent of TRD; however, this information was not reported in the reviewed studies and hence cannot be included. We agree that describing persistent depression within the text would be helpful. We have incorporated this suggestion by creating a new table (Table 2) that describes the various definitions of persistent depression, and summarizes antidepressant type, dosage, and duration. The Additional information about prior antidepressant treatment was also added to the definitions of persistent depression in the evidence tables in the appendices.
2 | e. Can the authors clarify whether any of the studies directly addressed the research question they pose? If not, how might they suggest designing a future research project to address this question directly? Also, might they suggest a study to address the long term risk benefits of a switch to CT (or an empirically based psychotherapy) vs medications? | e. A sentence was added to the discussion on page 30 clarifying our position that we do not consider the initial key research question adequately answered by our review. Regarding the reviewer’s suggestion of designing a study, our current version outlines important components of such a study in the Future Research section (pg 35) as well as highlights these in the Summary and Discussion section. Specifically, we highlight the need to study TRD in the context of impact on work, medical comorbidities, relapse, and the need for cost-effectiveness analysis of the different treatments available.
3 | This report looked at the condition of treatment resistant major depression that failed to respond to an adequate dose of antidepressant treatment. I wonder if it would be worth looking at individuals who have treatment resistant major depression that failed to respond to an adequate dose of antidepressant treatment? I know of two recent studies that may be worth reviewing: Watchful waiting for minor depression in primary care: remission rates and predictors of improvement. M.T. Hegel et al. General Hospital Psychiatry 28 (2006) 205–212. This study suggests that for treatment-seeking samples with minor depression in primary care an avoidant coping style seriously interferes with remission, and engaging in regular active pleasant events confers an advantage. It further suggests that feasible interventions for primary care that promote activity and decrease avoidant coping styles may improve outcomes. Cortico-limbic response to personally challenging emotional stimuli after complete recovery from depression. J.M. Hooley et al. Psychiatry Research: Neuroimaging 171 (2009) 106–119. This study suggests that vulnerability to depression may be associated with abnormalities in cortico-limbic activation that are independent of mood state and that remain even after full recovery. Perhaps there are similar processes at work in those with treatment resistant major depression that failed to respond to an adequate dose of antidepressant treatment that would not respond to traditional psychotherapeutic approaches. | The reviewer makes an interesting point. The Hegel study suggests that patients with minor depression may be successfully treated in primary care through pleasant activities and by reducing avoidant coping. The extensive literature on coping and depression supports this conclusion. It is likely that patients with minor depression may be patients who have residual symptoms after an MDD episode, in other words, TRD. However, it seems that a discussion of such interventions is beyond the scope of this review because of our original goal of comparing CT with medications in a treatment resistant population. Future reviews may address this issue by incorporating all treatments provided in primary care settings, and treatments provided to patients who may or may not have TRD. Regarding the Hooley study, it would be certainly worthwhile to determine the neurological mechanisms that may contribute to TRD and/or relapse. Unfortunately, a discussion of such mechanisms is beyond the scope of this review as defined by the VA Central office.
Question 5: Recommendations for future ESP topical areas of interest or programmatic comments may also be included at the end of this section.
Reviewer | Comment | Reply
1 | No comment | Acknowledged
2 | None
3 | I agree wholeheartedly with the statement on page 34 that there remains a need for trials of depression treatments to inform the specific treatments offered (and to be offered) in primary care mental health integration models. This is a pressing need. I would argue that the population of patients that could benefit from efficacious and effective treatments in such models is far larger than the population of patients who suffer from treatment resistant depression. | Acknowledged