# SEARCH STRATEGY

Question: In primary care patients with major depressive disorder who do not achieve remission with acute phase antidepressant treatment, is empirically based psychotherapy used as an augmentation or substitution treatment more effective than control for achieving remission? Empirically based psychotherapies to be considered are: cognitive behavioral therapy, interpersonal therapy, problem-solving therapy, dialectical behavior therapy, and acceptance and commitment therapy.

## Inclusion Criteria-Systematic Reviews

Systematic Review

Does psychotherapy benefit patients who have been previously not responded to adequate pharmacotherapy?

Search Strategy for Systematic Review: Database: PubMed Medline – 1950 to February 26, 2009

1 | “Depressive Disorder”[Mesh] OR (major AND depression) | 71993
2 | ((problem-solving OR interpersonal OR dialectical behav* OR acceptance OR commitment OR mindfulness) AND (therapy OR psychotherapy)) OR “Psychotherapy”[Mesh] OR “Behavior Therapy”[Mesh] | 229473
3 | (“Combined Modality Therapy”[Mesh] OR Drug resistant[Mesh] OR additive OR augmentation OR augment* OR relaps* OR recurrent OR refractory OR resistant OR persisten* OR treatment failure[Mesh]) | 1147546
4 | #1 AND #2 AND #3 | 1997
5 | Limits: Humans, English, All Adult: 19+ years | 1078
6 | systematic[sb] | 116759
7 | #5 AND #6 | 34
8 | Cochrane Database Syst Rev [TA] OR search[Title/Abstract] OR meta-analysis[Publication Type] OR MEDLINE[Title/abstract] OR (systematic[Title/Abstract] AND review[Title/Abstract]) | 140388
9 | #5 AND #8 | 24
10 | #7 OR #9 | 41

For Systematic Reviews, the Medline search yielded 41 articles. Title and abstracts were reviewed by 2 independent persons who identified 12 articles for full text review. Of the 12 reviewed, 0 were identified as meeting the inclusion criteria previously established; therefore no systematic reviews will be included for this question in the final report.

## Inclusion Criteria-Randomized Controlled Trials

Randomized controlled trials

Outpatient setting

Patients from general population (not special populations)

Adults who have not remised or responded significantly to antidepressant medication for > 6 wks and not in therapy (CBT, IPT, Sol. Focused, DBT, ACT, MBT)

If mixed sample, at least 80% must be partial or non-responders or outcomes reported separately

Exclude: patients with MDD where guidelines recommend mental health specialty care (eg. high suicidality, substance abuse, borderline personality d/o)

Relevant comparison

English language articles

Search Strategy for Randomized Controlled Trials: Database: PubMed Medline - 1950 to February 26, 2009

1 | “Depressive Disorder”[Mesh] OR (major AND depression) | 71993
2 | ((problem-solving OR interpersonal OR dialectical behav* OR acceptance OR commitment OR mindfulness) AND (therapy OR psychotherapy)) OR “Psychotherapy”[Mesh] OR “Behavior Therapy”[Mesh] | 229441
3 | “Combined Modality Therapy”[Mesh] OR Drug resistant[Mesh] OR additive OR augmentation OR augment* OR relaps* OR recurrent OR refractory OR resistant OR persisten* OR treatment failure[Mesh] | 1147546
4 | randomized controlled trial[Publication Type] OR (randomized[Title/Abstract] AND controlled[Title/Abstract] AND trial[Title/Abstract]) | 275228
5 | #1 AND #2 AND #3 AND #4 | 422
6 | Limits: Humans, English, All Adult: 19+ years | 333

For Randomized Control Trials, the Medline search yielded 333 articles. Title and abstracts were reviewed by 2 independent persons who identified 43 articles for full text review. Of the 43 articles reviewed, 12 were identified as meeting the inclusion criteria previously established.