# RESULTS

From 7,843 titles and abstracts, 286 articles were selected for full-text review (Figure available as online supplement). Of these, 30 studies of 26 unique models across a broad variety of settings and patient populations met our inclusion criteria (Table 1). Most (N=23) studies were based on US healthcare data. The remainder were from Australia (2 studies), England (2), Ireland (1), Switzerland (1), or Canada (1). Fourteen studies included only patients at least 65 years of age. Of these, seven relied solely on Medicare administrative data. Four studies used VA data.

TABLE 1 Characteristics of validated readmission risk prediction models

Study | Population | Setting | No. of patients, derivation cohort | No. of patients, validation cohort^*^ | Utilization outcome^†^ | Actual readmission rate (% of patients) | | Range of readmission rates according to predicted risk (validation cohort) | Model discrimination (c-statistic^‡^ unless specified otherwise)
Study | Population | Setting | No. of patients, derivation cohort | No. of patients, validation cohort^*^ | Utilization outcome^†^ | Derivation cohort | Validation cohort | Range of readmission rates according to predicted risk (validation cohort) | Model discrimination (c-statistic^‡^ unless specified otherwise)
Models relying on retrospective administrative data
Anderson, 1985^22^ | Medicare patients (excluded ESRD pts), 1974-1977 | US, general population | 21043 | 10522 | 60-day readmissions | NR | NR | 4 – 40 (lowest to highest decile)^§^ | NR
Bottle, 2006^12^ | Inpatients, 2000-2001 | England, general population | ∼1373755^‖^ | ∼1373754^‖^ | 12-month readmissions | 9.80 overall | | --- | All patients: 0.72 Patients with ambulatory care sensitive conditions^¶^: 0.75 All patients (12 month deaths excluded): 0.70
CMS model, AMI Krumholz 2008^16^ | Medicare AMI patients ≥ 65 yr, 2005-2006 | US, general population | 100465 | 100285 | 30-day readmissions | 18.9 | 19.2 | 8.0 – 33.0 (lowest to highest decile) | 0.63
CMS model, CHF Krumholz, 2008^15^ | Medicare CHF patients ≥ 65 yr, 2003-2004 | US, general population | 283919 | 283528 | 30-day readmissions | 23.6 | 23.7 | 15.0 - 37.0 (lowest to highest decile | 0.6
CMS model, Pneumonia Krumholz, 2008^17^ | Medicare pneumonia patients ≥ 65 yr, 2005-2006 | US, general population | 226545 | 226706 | 30-day readmissions | 17.4 | 17.5 | 9.0 – 31.0 (lowest to highest decile) | 0.63
Halfon, 2006^13^ | All hospitalizations in year 2000 | Switzerland, general population | 65740 | 66069 | 30-day potentially avoidable readmissions | 5.1 | 5.2 | --- | Nonclinical: 0.67 Charleson based: 0.69 SQLape: 0.72
Hammill, 2011^18^ | CHF registry patients ≥ 65 yr, 2004-2006 | US. general population | 24163^#^ | | 30-day readmissions | 21.9 overall | | Claims-only: 14.4 – 32.7 (lowest to highest decile) Claims-clinical: 13.5 – 33.9 | Claims-only: 0.59 Claims-clinical: 0.60
Holloway, 1990^53^ | Medical, neurologic, surgical, and geriatric inpatients, 1981-1982 | US, single VA hospital | 2970 | unclear | 30-day readmissions | 22.0 overall | | --- | NR
Holman, 2005^14^ | Medical, surgical, psychiatric inpatients, 1989-1997 | Western Australia, general population | 326,456 | 5289 (asthma) 5265 (AMI) | 30-day readmissions | NR | NR | --- | Asthma 0.71 AMI 0.64
Howell, 2009^54^ | General medical inpatients with ambulatory care sensitive condition^¶^ 2005-2006 | Queensland, Australia, general population | 13207 | 4492 | 12-month readmissions | 45.5 | 45.1 | LR+ readmission for risk scores 50, 70, 80: 2.04, 3.11, 7.02 (overall range 0 – 100) | 0.65
Naessens, 1992^23^ | Inpatients ≥ 65 yr, 1980, 1985, and 1987 | US, general population in a single county | 5854 | randomly selected10% of derivation cohort | 60-day mortality/readmissions | 20.8 overall | | 15.6 – 36.0 (lowest to highest quartile) | HCFA alone 0.59 (SE=0.01) HCFA + COMPLEX 0.61 (SE=0.01)
Philbin, 1999^19^ | CHF inpatients, 1995 | US, multicenter in a single state | 21227 | 21504 | CHF readmissions within calendar year | 21.3 overall | | 9.8 – 45.4 (lowest to highest ninth) | Simple scoring system: 0.60 Weighted scoring system: 0.61
Silverstein, 2008^20^ | Inpatients ≥ 65 yr, 2002-2004 | US, multicenter in a single city | 19528 | 9764 | 30-day readmissions | 11.7 overall | | --- | 0.65 (same for both Elixhauser and HRDES methods)
Thomas, 1996^21^ | Medicare inpatients ≥ 65 yr, 1989-1991 | US, multicenter in a single state | 12 different cohorts based on diagnosis; range 1163-14590 | | 15-, 30-, 60-, and 90-day readmissions | 3 - 40^**^ overall | | --- | among 8 medical conditions and 4 time periods, c statistic ranged from 0.55-0.61
Models using administrative data in real time
Amarasingham, 2010^24^ | CHF patients, 2007-2008 | US, single center | 1029 | 343 | 30-day readmissions | 24.1 overall | | 12.2 – 45.7 (lowest to highest quintile) | 0.72 (0.70-0.75)
Billings, 2007^25^ | Patients eligible for mandatory Medicaid managed care enrollment, 2000-2004 | US, general population in a single city | ∼35000^‖^ | ∼35000^‖^ | 12-month readmissions | NR | NR | NR (inpatient costs ranged 23,687 – 44,385 for risk scores 50-90, overall range 0 – 100) | Risk scores range 0-100 Using risk score 50+, Sens 58%, Spec 74%, PPV 69.5%, LR+ 2.23
PARR model Billings, 2006^26^ | Inpatients with an ambulatory care sensitive reference condition^¶^ 2002-2003 | England, general population | 10% of hospital episodes for all England | A second 10% sample of hospital episodes for all England | 12-month readmissions | NR | NR | --- | 0.69
Models using retrospective primary data collection
Coleman, 2004^27^ | Medicare inpatients ≥ 65 yr, 1997-1998 | US, general population | 700 | 704 | 30-day “complicated care transitions”^††^ | 21.9 | 25.0 | --- | administrative data model: 0.77 administrative + self-report data: 0.83
Krumholz, 2000^30^ | Medicare CHF patients ≥ 65 yr, 1994-1995 | US, multicenter in a single state | 1129 | 1047 | 180-day readmissions | 50.0 | 47.0 | All-cause: 26.0 – 59.0 CHF: 9.0 – 31.0 (lowest to highest tertile) | Number of risk factors associated with readmission risk (P<0.0001). 0 risk factors: 26% 3-4 risk factors: 59%
Morrissey, 2003^28^ | Medical inpatients ≥ 65 yr, 1997- 1998 | Ireland, single rural hospital | 487 | 732 | 12-month readmissions | 40.7 | 29.0 | --- | 0.70
Smith Index (original) Smith, 1985^55^ | Medical inpatients, 1979-1980 | US, single county hospital | 1007 | 499 | 90-day readmissions | 16.9 | NA | 7.3 – 38.0 (lowest to highest octile) | Sens 59.0%, Spec 69.3%, PPV 29.9% LR+ 1.92
Smith Index validation Smith, 1988^56^ | Medical inpatients, 1985 | US, single county hospital | 502 (control) 499 (intervention) | | Readmissions/month/patient (mean 180 days f/u) | NA | 10.0 | 0.07 – 0.18 (lowest to highest tertile) | NR
Smith Index validation Smith, 1996^57^ | Medical inpatients ≥ 45 yr, 1988- 1990 | US, single VA hospital | | 662 (validation) | 90-day readmissions | NA | 20.1 | --- | 0.66
Van Walraven, 2010^29^ | Medical and surgical inpatients | Canada, multicenter | 4812 patients — split derivation/internal validation | 1M patients from Discharge Abstract Database for external validation | 30-day readmissions | 7.3 | 7.3 | 0 – 42.9 (scores 0 – 17, footnote – corresponding to expected probability of readmission/death of 2.0 – 34.6%) | 0.68 (0.65-0.71)
Models using primary data collected in real time
Burns, 1991^58^ | Medical inpatients ≥ 65 yr, 1987 | US, single VA hospital | 134 | 34 | 60-day readmissions | 30.6 overall | | --- | NR
Evans, 1988^59^ | Medical, neurologic, and surgical inpatients over a 6 week period | US, single VA hospital | 532 | 177 | Composite of 60-day readmission, nursing home placement, or LOS longer than expected per mean LOS of DRG | 21.0 overall (60-day readmissions) | | % high-care users: 34.7 – 91.7 (lowest to highest eighth) | Risk score range 0-8 Score >= 3: Sens 0.60, Spec 0.76, LR+ 2.5 Score >= 4: Sens 0.42, Spec 0.93, LR+ 6
Hasan, 2009^31^ | Medical inpatients, 2001-2003 | US, multicenter | 7287 | 3659 | 30-day readmissions | 17.5 | 17.4 | 5.9 – 28.9 (lowest to highest quartile) | 0.61
PRA (original) Boult, 1993^32^ | Non-institutionalized Medicare patients ≥ 70 yr, 1984 | US, general population | 2942 | 2934 | 4 year readmissions | 28.4 | NA | 26.1 (score 0-3) – 41.8 (score 4+) | 0.61 (SE=0.01)
PRA validation Allaudeen, 2011^34^ | Medical inpatients ≥ 65 yr, 5 week period in 2008 | US., single academic center | NA | 159 | 30-day readmissions | NA | 32.7 | --- | PRA 0.56 (0.44-0.67) Prediction by physician 0.58-0.59 (0.46-0.70) Prediction by non-physician provider 0.50-0.55 (0.38 – 0.67)
PRA validation Novotny, 2008^33^ | Medical inpatients, 2005-2007 | US, single academic center | 1077 | | 41-day readmissions | NA | 14.0 | --- | PRA score 0.53 cutpoint, LR+ 1.67

Abbreviations: DRG denotes Diagnosis Related Group; LR+, Positive Likelihood Ratio; NA, Not Applicable; NR, Not Reported; PARR, Patients at Risk for Re-hospitalization algorithm; PRA, Probability of Repeated Admissions; SE, Standard Error.

* The most recent validation cohort is listed if a study had multiple validation cohorts.

† Unplanned, all-cause readmissions unless otherwise specified

‡ Validation cohort values for the c-statistic are listed if a study provided c-statistic values for both validation and derivation cohorts. 95% confidence interval is provided in parentheses, if reported.

§ Approximate values of data presented in a bar graph.

‖ The total number of subjects was divided equally between the derivation and validation cohorts, but the exact numbers were not specified.

¶ Reference conditions such as congestive heart failure, chronic obstructive pulmonary disease, diabetes, and asthma, for which timely and effective case-management has the potential to reduce the risks of readmission.

# Used bootstrap method for internal validation, no separate validation cohort

** Reports 15-, 30-, 60-, and 90-day readmission rates for 12 different conditions

†† At least one transfer from lower to higher intensity care environment

Figure 1 Risk Prediction Models for Hospital Readmission - Literature Flow

Total sample size ranged from just 173 patients to more than 2.7 million. The outcome of 30-day readmission was reported most commonly, though some models chose other follow-up intervals ranging from 14 days to 4 years. Among 21 studies reporting a c-statistic, values ranged from 0.55 – 0.83 (Table 1), but only six studies reported a c-statistic above 0.70 indicating modest discriminative ability. Performance was similar between studies using split-sample validation methods (n=21, c-statistic range 0.59-0.75), and those that used external validation methods (n=9, c-statistic range 0.53-0.83). Among models that analyzed the relationship between risk categories and actual readmission rates, a substantial gradient in readmission rate was present between patients at the lowest vs. the highest risk level. For example, among six models using 30-day readmission as an outcome, the lowest and highest risk groups differed by 20.4 to 34.5 percentage points in their actual readmission rates.

## Models Relying on Retrospective Administrative Data

Fourteen models were based on retrospective administrative data and could potentially be used for hospital comparison purposes (Table 1). Most of these included medical comorbidity and prior utilization variables, but few considered mental health, functional status and social determinant variables (Table 2). The three models with c-statistics ≥ 0.70 were developed and tested in large European or Australian cohorts. One examined the risk of two or more unplanned readmissions for all hospitalized patients in England, including pediatric and obstetric patients, for one calendar year.12 A Swiss study of potentially preventable readmissions is described in greater detail below.13 An Australian model incorporating over 100 medical comorbidities and administrative social determinant variables performed at a modest level in asthma patients, but poorly in myocardial infarction patients.14

TABLE 2 Variables considered by studies in evaluating the risk of readmission

Variable | Included in final model in (N) studies | Evaluated but not included in (N) studies | Not considered* in (N) studies
Medical comorbidities
Specific diagnoses or comorbidity index | (24) 12-21, 23, 25-32, 53, 54, 57-59 | (0) | (3) 22, 24, 55
Mental health comorbidities
Mental illness | (9) 13-15, 17, 18, 24, 25, 54, 59 | (4) 16, 20, 26, 58 | (11) 19, 22, 23, 28-32, 53, 55, 57
EtOH/substance use | (11) 13-15, 17-19, 24-26, 53, 54 | (5) 16, 20, 28, 57, 59 | (8) 22, 23, 29-32, 55, 58
Illness severity
Illness severity index | (1) 24 | (1) 58 | (19) 12, 13, 15-18, 20, 23, 26, 28-32, 53-55, 57, 59
Lab findings | (4) 18, 30, 55, 57 | (1) 28 | (15) 12, 13, 15-17, 20, 23, 26, 29, 31, 32, 53, 54, 58, 59
Other^†^ | (4) 2, 3, 20, 2 | (4) 18, 30, 57, 59 | (11) 15-17, 20, 26, 28, 29, 31, 32, 54, 55
Prior utilization
Hospitalizations | (14) 12, 13, 22, 24-28, 30-32, 54, 58, 59 | (1) 29 | (10) 15-20, 23, 53, 55, 57
ER visits | (4) 25, 29, 55, 57 | (1) 24 | (17) 15-20, 22, 23, 26, 28, 30-32, 53, 54, 58, 59
Clinic visits/Missed clinic visits | (3) 24, 25, 32 | (0) | (19) 15-20, 22, 23, 26, 28-31, 53-55, 57-59
Index hospital length of stay | (4) 19, 21, 29, 31 | (3) 30, 53, 58 | (15) 15-18, 20, 22-24, 26, 28, 32, 54, 55, 57, 59
Overall health and function
Functional status; ADL dependence; mobility | (2) 27, 57 | (6) 29-32, 58, 59 | (14) 15-20, 22-24, 26, 28, 53-55
Self-rated health, quality of life | (3) 27, 31, 32 | (2) 28, 57 | (17) 15-20, 22-24, 26, 29, 30, 53-55, 58, 59
Cognitive impairment | (7) 15-18, 28, 57, 59 | (5) 20, 31, 32, 54, 58 | (9) 19, 22-24, 26, 29, 30, 53, 55
Visual or hearing impairment | (1) 27 | (1) 32 | (21) 15-20, 22-24, 26, 28-32, 53-55, 57-59
Sociodemographic factors
Age | (19) 12-18, 20-23, 25-27, 32, 53, 54, 57, 59 | (7) 19, 24, 29-31, 55, 58 | (1) 28
Gender | (15) 12-18, 20-26, 32 | (8) 19, 29-31, 53-55, 58 | (1) 28
Race/ethnicity | (7) 12, 14, 19, 20, 22, 25, 26 | (8) 24, 30-32, 54, 55, 57, 58 | (8) 15-18, 23, 28, 29, 53
Social determinants of health
SES/income/employment status | (5) 12, 14, 24, 25, 54 | (7) 20, 26, 31, 32, 57-59 | (10) 15-19, 22, 23, 28, 29, 53
Insurance status^‡^ | (6) 19, 20, 24, 27, 31, 53 | (1) 57 | (5) 30, 32, 55, 58, 59
Education | (0) | (4) 28, 31, 32, 58 | (17) 15-20, 22-24, 26, 29, 30, 53-55, 57, 59
Marital status/# of people in home | (4) 24, 28, 31, 59 | (6) 29, 32, 53, 54, 57, 58 | (11) 15-20, 22, 23, 26, 30, 55
Caregiver availability, other social support | (2) 32, 57 | (1) 31 | (19) 15-20, 22-24, 26, 28-30, 53-55, 57-59
Access to care/rurality | (5) 19, 22, 31, 53, 54 | (2) 20, 29 | (14) 15-18, 23, 24, 26, 28, 30, 32, 55, 57-59
Discharge location (home, NH) | (2) 19, 20 | (1) 53 | (18) 15-18, 22-24, 26, 28-32, 54, 55, 57-59

Six studies did not report candidate variables and only reported the final model.12-14, 21, 25, 27

† Examples include use of telemetry, shock, planned vs emergent index hospitalization, heart rate, ejection fraction.

‡ This category is not relevant to studies of Medicare patients15-18, 23 and non-US studies.12, 13, 28, 29, 54

The nine large population-based or multicenter US studies generally had poor discriminative ability (c-statistics 0.55 – 0.65). The CMS used a methodologically rigorous process to create three models for congestive heart failure, acute myocardial infarction, and pneumonia admissions based on Hierarchical Condition Categories, which are groups of related comorbidities.15-17 All three models showed relatively poor ability to predict 30-day all cause readmissions (c-statistics 0.61, 0.63, and 0.63, respectively). A recent study evaluating the CMS heart failure model, and an older heart failure model fared similarly (c-statistics 0.59 and 0.61, respectively).18, 19 The other four US models have limited generalizability: one captured readmissions to one medical center only,20 and the others were developed over two decades ago.21-23

## Models Using Real-Time Administrative Data

Three administrative data-based models were designed to identify high-risk patients in realtime to potentially facilitate targeted interventions. A model with modest discriminative ability (c-statistic 0.72, 95% CI 0.70-0.75) examined 30-day heart failure readmissions in a single urban US health system with a large socioeconomically disadvantaged population.24 It incorporated variables from an automated electronic medical record system, including numerous social factors such as number of address changes, census tract socioeconomic status, history of cocaine use, and marital status. The only study focused specifically on Medicaid enrollees used a 0 to 100 risk score for 12-month readmissions and found patient cost profiles varied widely with risk score.25 Finally, a British model used prior utilization and comorbidity data, and also controlled for observed to expected readmission rates for the admission hospital, but predictive ability remained modest (c-statistic 0.69).26

## Models Incorporating Primary Data Collection

Nine models incorporated survey or chart review data and could potentially be used for clinical intervention purposes, though five used data unlikely to be available early during a hospitalization. The best performing of these used administrative comorbidity and prior utilization data (c-statistic 0.77) along with functional status data (c-statistic 0.83) from the Medicare Beneficiaries Survey to predict a composite outcome of readmissions and nursing home transfers.27 The survey was not routinely administered during index hospitalization and it is unclear to what extent the use of retrospective survey data affects the predictive ability of the model. Similarly, a medical record study in Ireland retrospectively applied a nine-item questionnaire, including items such as discharge polypharmacy, and performed modestly well (c-statistic 0.70).28 A simple Canadian model used medical comorbidities up through index hospital discharge along with index hospital length of stay and prior utilization (c-statistic 0.68, 95%CI 0.65-0.71).29 Increasing scores on another four-item model of medical comorbidities, prior utilization and discharge creatinine were associated with increasing readmission rates in heart failure patients.30

Four models incorporated primary data collected in real-time. Only two of these models have been tested in contemporary populations, the others having been conducted more than two decades ago. One survey-based model developed at six academic hospitals included social determinant, comorbidity, utilization, and self-rated health variables, but had poor predictive ability (c-statistic 0.61).31 The Probability of Repeated Admissions (PRA) is a simple eight-item survey tool developed in older Medicare beneficiaries, but it also had poor predictive ability across several studies (c-statistic 0.56–0.61, 95% CI 0.44-0.67).32-34

## Use of variables

A comparison of the types of variables considered for, and included in, the final models can provide some information about the contribution of different types of variables to readmission risk prediction (Table 2). Nearly all studies included medical comorbidity data and many included prior utilization variables, usually prior hospitalizations. Basic sociodemographic variables such as age and gender were considered by most studies but, in many instances, these variables did not contribute enough to be included in the final model. Table 2 also highlights important gaps in model development: few studies considered variables associated with illness severity, overall health and function, and social determinants of health.

Six studies that compared the performance of different models within the same population offer further insights about the incremental value of different types of variables (Table 3). Amarasingham and colleagues found that an automated electronic medical record-based model incorporating sociodemographic factors such as drug use and housing discontinuities, was more predictive than comorbidity-based models.24 Coleman and colleagues found the inclusion of variables such as functional status from survey data improved model performance slightly compared to the use of utilization and comorbidity-based administrative data alone (c-statistics 0.83 vs 0.77).27

TABLE 3 Studies that compared models within a population

Study and models compared | Model description | C-statistic (95% CI or SE if reported)
Halfon, 2006^13^
Nonclinical model | Age, sex, prior utilization | 0.67
Modified Charlson score based model | Charlson score60 plus prior utilization | 0.69
Modified SQLape model61 | Complex administrative model combining comorbidity, age, and utilization data into 49 risk categories | 0.72
Hammill 2011^18^
Claims-only model | CMS administrative heart failure model15 | 0.59
Claims-clinical model | CMS heart failure model + serum creatinine, serum sodium, hemoglobin, systolic blood pressure | 0.60
Allaudeen, 2011^34^
PRA^*,32^ | Age, sex, self-rated health, availability of informal caregiver, coronary disease, diabetes, hospital admission within past year, prior utilization | 0.56 (0.44-0.67)
Prediction by physician | Interns, residents, and attending physicians predicted chance of readmission based on overall evaluation of patient | 0.58-0.59 (0.46-0.70)
Prediction by non-physician provider | Nurses and case managers predicted chance of readmission based on overall evaluation of patient | 0.50-0.55 (0.38-0.67)
Amarasingham, 2010^24^
ADHERE mortality model | Blood urea nitrogen, creatinine, and systolic blood pressure | 0.56 (0.54-0.59)
CMS heart failure model15 | Complex administrative comorbidity model consisting of age, sex, and 35 hierarchical condition categories | 0.66 (0.63-0.68)
Tabak mortality model62 | Age, 17 lab and vital sign variables within 24 hours of hospital presentation | 0.61 (0.59-0.64)
Electronic readmission model | Includes Tabak mortality score, history of depression or anxiety, single status, sex, residential stability, Medicare status, residence census tract in lowest socioeconomic quintile, history of confirmed cocaine use, history of missed clinic visit, use of a health system pharmacy, number of prior admissions, presented to emergency department between 6 am and 6 pm for index admission. | 0.72 (0.70-0.75)
Coleman, 2004^27^
Administrative model | Age, sex, prior utilization, Medicaid status, Charlson score,60 heart disease, cancer, diabetes | 0.77
Administrative + self-report model | Administrative model + self-rated health, ADL assistance need, visual impairment, functional status | 0.83
Naessens, 1992^23^
Modified Health Care Financing Administration (HCFA) mortality model63 | Age, sex, 16 DRG, and 8 comorbidities | 0.59 (SE=0.01)
HCFA + COMPLEX | Complicated administrative model incorporating DRG based disease staging and number of body systems affected + HCFA | 0.61 (SE=0.01)

Abbreviations: ADHERE denotes Acute Decompensated Heart Failure Registry; CI, Confidence Interval; CMS, Center for Medicaid and Medicare Services; COMPLEX, a measurement of comorbidity and disease severity;23 HCFA, Health Care Financing Administration; IDI, Integrated Discrimination Improvement; PRA, Probability of Repeated Admission; SE, Standard Error.

* Variables were obtained from chart abstraction, whereas original PRA instrument is based on patient surveys.

Other comparative studies found little difference among models.Clinical data, such as laboratory and physiologic variables, from medical records or registries did not enhance performance of claims-only CMS models.15-17, 28 A US study of older patients found that an intricate ICD-9 code based disease complexity system added very little discriminative ability to a poorly performing Health Care Financing Authority model.23 A large Swiss study of potentially preventable readmission risk compared a very simple non-clinical model, a Charlson comorbidity-based model, and a more complex hierarchical diagnosis and procedures based model called SQLape, finding only slight differences among them (c-statistics 0.67, 0.69, and 0.72, respectively).13 Finally, Allaudeen and colleagues found internal medicine interns using a gestalt approach predicted readmissions with a similar poor level of ability as an older, established survey-based model (PRA) in a small, single center cohort.34

## Potentially preventable readmissions

Only one model attempted to explicitly define and identify potentially preventable readmissions.35 Investigators conducted a systematic medical record review to define potentially preventable readmissions and develop an administrative data-based algorithm. A subsequent publication (described above) compared the performance of three models in predicting readmissions according to their algorithm.13