# REFERENCES

1 Jack BW, Chetty VK, Anthony D, et al. A reengineered hospital discharge program to decrease rehospitalization: a randomized trial. Ann Intern Med. Feb. 3. 2009;150(3):178-187. [pmid: 19189907].
2 Coleman EA, Parry C, Chalmers S, et al. The care transitions intervention: results of a randomized controlled trial. Arch Intern Med. Sep. 25. 2006;166(17):1822-1828. [pmid: 17000937].
3 Naylor MD, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. Jama. Feb. 17. 1999;281(7):613-620. [pmid: 10029122].
4 QualityNet. Readmission Measures Overview - Publicly reporting risk-standardized, 30-day readmission measures for AMI, HF and PN. http://www.qualitynet.org/dcs/ContentServer?cid=1219069855273&pagename=QnetPublic%2FPage%2FQnetTier2&c=Page. 5/28/2011.
5 Krumholz HM, Brindis RG, Brush JE, et al. Standards for statistical models used for public reporting of health outcomes: an American Heart Association Scientific Statement from the Quality of Care and Outcomes Research Interdisciplinary Writing Group: cosponsored by the Council on Epidemiology and Prevention and the Stroke Council. Endorsed by the American College of Cardiology Foundation. Circulation. Jan. 24. 2006;113(3):456-462. [pmid: 16365198].
6 McGinn TG, Guyatt GH, Wyer PC, Naylor CD, Stiell IG, Richardson WS. Users' guides to the medical literature: XXII: how to use articles about clinical decision rules. Evidence-Based Medicine Working Group. Jama. Jul. 5. 2000;284(1):79-84. [pmid: 10872017].
7 Centers for Disease Control and Prevention. Establishing a Holistic Framework to Reduce Inequities in HIV, Viral Hepatitis, STDs, and Tuberculosis in the United States. Atlanta (GA). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. October. 2010. The report is available at: www.cdc.gov/socialdeterminants.
8 Iezzoni LI, editor. Risk adjustment for measuring health care outcomes. 3rd ed. Chicago IL. Health Administration Press. 2003.
9 Schneeweiss S, Seeger JD, Maclure M, Wang PS, Avorn J, Glynn RJ. Performance of comorbidity scores to control for confounding in epidemiologic studies using claims data. Am J Epidemiol. Nov. 1. 2001;154(9):854-864. [pmid: 11682368].
10 Ohman EM, Granger CB, Harrington RA, Lee KL. Risk stratification and therapeutic decision making in acute coronary syndromes. Jama. Aug. 16. 2000;284(7):876-878. [pmid: 10938178].
11 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. Mar. 21. 2006;144(6):427-437. [pmid: 16549855].
12 Bottle A, Aylin P, Majeed A, Bottle A, Aylin P, Majeed A. Identifying patients at high risk of emergency hospital admissions: a logistic regression analysis. J R Soc Med. Aug. 2006;99(8):406-414. [pmid: 16893941].
13 Halfon P, Eggli Y, Pretre-Rohrbach I, Meylan D, Marazzi A, Burnand B. Validation of the potentially avoidable hospital readmission rate as a routine indicator of the quality of hospital care. Med Care. Nov. 2006;44(11):972-981. [pmid: 17063128].
14 Holman CDAJ, Preen DB, Baynham NJ, Finn JC, Semmens JB. A multipurpose comorbidity scoring system performed better than the Charlson index. J Clin Epidemiol. Oct. 2005;58(10):1006-1014. [pmid: 16168346].
15 Krumholz H, Normand S, Keenan P, et al. Hospital 30-Day Heart Failure Readmission Measure: Methodology. Report prepared for Centers for Medicare & Medicaid Services. 2008.
16 Krumholz HM, Normand ST, Keenan PS, et al. Hospital 30-Day Acute Myocardial Infarction Readmission Measure: Methodology. A report prepared for the Centers for Medicare & Medicaid Services. 2008.
17 Krumholz HM, Normand ST, Keenan PS, et al. Hospital 30-Day Pneumonia Readmission Risk Measure: Methodology. A report prepared for the Centers for Medicare & Medicaid Services. 2008.
18 Hammill BG, Curtis LH, Fonarow GC, et al. Incremental value of clinical data beyond claims data in predicting 30-day outcomes after heart failure hospitalization. Circulation: Cardiovascular Quality and Outcomes. 2011;4(1):60-67. [pmid: 21139093].
19 Philbin EF, DiSalvo TG. Prediction of hospital readmission for heart failure: development of a simple risk score based on administrative data. J Am Coll Cardiol. May. 1999;33(6):1560-1566. [pmid: 10334424].
20 Silverstein MD, Qin H, Mercer SQ, Fong J, Haydar Z. Risk factors for 30-day hospital readmission in patients <GT> or = 65 years of age. Baylor University Medical Center Proceedings. 2008;21(4):363-372. [pmid: 18982076].
21 Thomas JW. Does risk-adjusted readmission rate provide valid information on hospital quality?. Inquiry. 1996;33(3):258-270. [pmid: 8883460].
22 Anderson GF, Steinberg EP. Predicting hospital readmissions in the Medicare population. Inquiry. 1985;22(3):251-258. [pmid: 2931368].
23 Naessens JM, Leibson CL, Krishan I, Ballard DJ. Contribution of a measure of disease complexity (COMPLEX) to prediction of outcome and charges among hospitalized patients. Mayo Clin Proc. Dec. 1992;67(12):1140-1149. [pmid: 1469925].
24 Amarasingham R, Moore BJ, Tabak YP, et al. An automated model to identify heart failure patients at risk for 30-day readmission or death using electronic medical record data. Med Care. Nov. 2010;48(11):981-988. [pmid: 20940649].
25 Billings J, Mijanovich T, Billings J, Mijanovich T. Improving the management of care for high-cost Medicaid patients. Health Aff (Millwood). Nov-Dec. 2007;26(6):1643-1654. [pmid: 17978384].
26 Billings J, Dixon J, Mijanovich T, Wennberg D. Case finding for patients at risk of readmission to hospital: development of algorithm to identify high risk patients. Bmj. Aug. 12. 2006;333(7563):327. [pmid: 16815882].
27 Coleman EA, Min SJ, Chomiak A, et al. Posthospital care transitions: patterns, complications, and risk identification. Health Serv Res. Oct. 2004;39(5):1449-1465. [pmid: 15333117].
28 Morrissey EFR, McElnay JC, Scott M, McConnell BJ. Influence of drugs, demographics and medical history on hospital readmission of elderly patients: A predictive model. Clinical Drug Investigation. 2003;23(2):119-128.
29 van Walraven C, Dhalla IA, Bell C, et al. Derivation and validation of an index to predict early death or unplanned readmission after discharge from hospital to the community. Cmaj. Apr. 6. 2010;182(6):551-557. [pmid: 20194559].
30 Krumholz HM, Chen YT, Wang Y, Vaccarino V, Radford MJ, Horwitz RI. Predictors of readmission among elderly survivors of admission with heart failure. Am Heart J. Jan. 2000;139(1 Pt 1):72-77. [pmid: 10618565].
31 Hasan O, Meltzer DO, Shaykevich SA, et al. Hospital readmission in general medicine patients: a prediction model. J Gen Intern Med. 2009;25(3):211-219. [pmid: 20013068].
32 Boult C, Dowd B, McCaffrey D, Boult L, Hernandez R, Krulewitch H. Screening elders for risk of hospital admission. J Am Geriatr Soc. Aug. 1993;41(8):811-817. [pmid: 8340558].
33 Novotny NL, Anderson MA. Prediction of early readmission in medical inpatients using the Probability of Repeated Admission instrument. Nurs Res. Nov-Dec. 2008;57(6):406-415. [pmid: 19018215].
34 Allaudeen N, Schnipper JL, Orav EJ, et al. Inability of providers to predict unplanned readmissions. J Gen Intern Med. Jul. 2011;26(7):771-776. [pmid: 21399994].
35 Halfon P, Eggli Y, van Melle G, Chevalier J, Wasserfallen JB, Burnand B. Measuring potentially avoidable hospital readmissions. J Clin Epidemiol. Jun. 2002;55(6):573-587. [pmid: 12063099].
36 Oddone EZ, Weinberger M, Horner M, et al. Classifying general medicine readmissions. Are they preventable? Veterans Affairs Cooperative Studies in Health Services Group on Primary Care and Hospital Readmissions. J Gen Intern Med. Oct. 1996;11(10):597-607. [pmid: 8945691].
37 Hernandez AF, Greiner MA, Fonarow GC, et al. Relationship between early physician follow-up and 30-day readmission among Medicare beneficiaries hospitalized for heart failure. Jama. May. 5. 2010;303(17):1716-1722. [pmid: 20442387].
38 Kripalani S, Jackson AT, Schnipper JL, et al. Promoting effective transitions of care at hospital discharge: a review of key issues for hospitalists. Journal of hospital medicine (Online). Sep. 2007;2(5):314-323.
39 Fisher E, Goodman D, Skinner J, Bronner K. Health Care Spending, Quality, and Outcomes - More Isn't Always Better. The Dartmouth Institute for Health Policy & Clinical Practice. 2009.
40 Ashton CM, Wray NP. A conceptual framework for the study of early readmission as an indicator of quality of care. Soc Sci Med. Dec. 1996;43(11):1533-1541. [pmid: 8961397].
41 Weissman JS, Ayanian JZ, Chasan-Taber S, Sherwood MJ, Roth C, Epstein AM. Hospital readmissions and quality of care. Med Care. May. 1999;37(5):490-501. [pmid: 10335751].
42 Fung CH, Lim YW, Mattke S, et al. Systematic review: the evidence that publishing patient care performance data improves quality of care. Ann Intern Med. Jan. 15. 2008;148(2):111-123. [pmid: 18195336].
43 The Care Transitions Quality Improvement Organization Support Center (QIOSC). http://www.cfmc.org/caretransitions. 6/1/11.
44 Ross JS, Mulvey GK, Stauffer B, et al. Statistical models and patient predictors of readmission for heart failure: a systematic review. Arch Intern Med. Jul. 14. 2008;168(13):1371-1386. [pmid: 18625917].
45 Joynt KE, Jha AK. Who has higher readmission rates for heart failure, and why? Implications for efforts to improve care using financial incentives. Circulation: Cardiovascular Quality and Outcomes. 2011;4(1):53-59. [pmid: 21156879].
46 Axon RN, Williams MV, Axon RN, Williams MV. Hospital readmission as an accountability measure. Jama. Feb. 2. 2011;305(5):504-505. [pmid: 21285430].
47 van Walraven C, Bennett C, Jennings A, et al. Proportion of hospital readmissions deemed avoidable: a systematic review. Cmaj. Apr. 19. 2011;183(7):E391-402. [pmid: 21444623].
48 Mukamel DB, Chou CC, Zimmer JG, Rothenberg BM. The effect of accurate patient screening on the cost-effectiveness of case management programs. Gerontologist. Dec. 1997;37(6):777-784. [pmid: 9432994].
49 Society of Hospital Medicine Project Boost Better Outcomes for Older Adults through Safe Transitions. Tool for Addressing Risk: A Geriatric Evaluation for Transitions. http://www.hospitalmedicine.org/ResourceRoomRedesign/RR_CareTransitions/PDFs/TAR-GET_screen_v22.pdf. 5/28/11.
50 Vest JR, Gamm LD, Oxford BA, et al. Determinants of preventable readmissions in the United States: a systematic review. Implement Sci. 2010;5:88. [pmid: 21083908].
51 Bahadori K, FitzGerald JM. Risk factors of hospitalization and readmission of patients with COPD exacerbation--systematic review. Int J Chron Obstruct Pulmon Dis. 2007;2(3):241-251. [pmid: 18229562].
52 Desai MM, Stauffer BD, Feringa HHH, Schreiner GC. Statistical models and patient predictors of readmission for acute myocardial infarction: a systematic review. Circulation. Sep. Cardiovascular Quality & Outcomes. 2009;2(5):500-507. [pmid: 20031883].
53 Holloway JJ, Medendorp SV, Bromberg J. Risk factors for early readmission among veterans. Health Serv Res. Apr. 1990;25(1 Pt 2):213-237. [pmid: 2109741].
54 Howell S, Coory M, Martin J, et al. Using routine inpatient data to identify patients at risk of hospital readmission. BMC Health Serv Res. 2009;9:96. [pmid: 19505342].
55 Smith DM, Norton JA, McDonald CJ. Nonelective readmissions of medical patients. J Chronic Dis. 1985;38(3):213-224. [pmid: 3988879].
56 Smith DM, Weinberger M, Katz BP, Moore PS. Postdischarge care and readmissions. Med Care. Jul. 1988;26(7):699-708. [pmid: 2839742].
57 Smith DM, Katz BP, Huster GA, Fitzgerald JF, Martin DK, Freedman JA. Risk factors for nonelective hospital readmissions. J Gen Intern Med. Dec. 1996;11(12):762-764. [pmid: 9016426].
58 Burns R, Nichols LO. Factors predicting readmission of older general medicine patients. J Gen Intern Med. Sep-Oct. 1991;6(5):389-393. [pmid: 1744751].
59 Evans RL, Hendricks RD, Lawrence KV, Bishop DS. Identifying factors associated with health care use: a hospital-based risk screening index. Soc Sci Med. 1988;27(9):947-954. [pmid: 3227391].
60 Charlson ME, Pompei P, Ales KL, MacKenzie CR. A new method of classifying prognostic comorbidity in longitudinal studies: development and validation. J Chronic Dis. 1987;40(5):373-383. [pmid: 3558716].
61 Eggli Y. Prévision des coûts hospitaliers fondés sur le profil des patients. Hospital costs prevision grounded on case-mix. Chardonne Switzerland. SQLape sa'rl. 2005.
62 Tabak YP, Johannes RS, Silber JH, Tabak YP, Johannes RS, Silber JH. Using automated clinical data for risk adjustment: development and validation of six disease-specific mortality predictive models for pay-for-performance. Med Care. Aug. 2007;45(8):789-805. [pmid: 17667314].
63 Bowen OR, Roper WL. Medicare Hospital Mortality Information, 1987. Region IX: American Samoa, Arizona, Guam, Hawaii, Nevada, Publication No. HCFA 00651. Washington, DC. US Government Printing Office. 1988.