# METHODS

## DATA SOURCES AND SEARCHES

We searched Ovid MEDLINE, CINAHL, and the Cochrane Library (Central Trial Registry, Systematic Reviews, and Abstracts of Reviews of Effectiveness) from database inception through March 2011, and EMBASE through August 2011, for English-language studies of readmission risk prediction models in medical populations. All citations were imported into an electronic database (EndNote X2, Thomson Reuters, New York, NY). Appendix A provides the search strategies in detail.

## STUDY SELECTION

Seven investigators reviewed the citations and abstracts identified from electronic literature searches. Full-text articles of potentially relevant references were retrieved for further review. Each article was independently assessed by two reviewers using the eligibility criteria shown in Appendix B. Eligible articles were published in English and evaluated the ability of statistical models to predict hospital readmission risk. Because a set of predictive factors derived in only one population may lack validity and applicability,6 we included only studies of models that were tested in both a derivation and validation cohort, even if these results were presented in separate papers. We did not pre-specify the method of validation, nor did we exclude studies in which the derivation and validation cohorts were drawn from the same population (i.e., split-half validation). We did not limit studies by diagnosis within medical populations, but we excluded studies focused on psychiatric, surgical, and pediatric populations as factors contributing to readmission risk might be considerably different in these patient groups,. Finally, we excluded studies from developing nations as these were unlikely to provide directly applicable results.

## DATA EXTRACTION AND QUALITY ASSESSMENT

From each study, we abstracted the following: population characteristics, setting, number of subjects in the derivation and validation cohorts, utilization outcome, readmission rate, range of readmission rates according to predicted risk, and model discrimination. To facilitate a high-level comparison of predictor variables, we grouped final model variables into one of six categories (medical comorbidity, mental health comorbidity, illness severity, prior utilization, overall health and function, and sociodemographic/social determinants of health).7

To characterize the practical utility of each model, two reviewers abstracted from each study the type of data used and the timing of data collection. Disagreements between reviewers about these classifications were resolved through group discussion. Data type consisted of administrative, primary (e.g., survey, chart review), or both. Regarding timing, we classified a model as using real-time data if the variables would be available on or shortly after index hospital admission, and as using retrospective data if the variables would not be available early during a hospitalization. For example, a model using prior healthcare utilization and data from patient surveys conducted early during a hospitalization would be classified as using real-time data, while a model using index hospital length of stay or index hospital discharge diagnostic codes would be classified as using retrospective data. Because of coding delays, models relying on administrative codes from index hospital admission were considered retrospective.

We report the c-statistic, with 95% confidence interval when available, to describe model discrimination. The c-statistic, which is equivalent to the area under the receiver operating characteristic curve, is the proportion of times the model correctly discriminates a pair of high- and low-risk individuals.8 A c-statistic of 0.5 indicates the model performs no better than chance; a c-statistic of 0.7 to 0.8 indicates modest or acceptable discriminative ability, and a threshold of greater than 0.8 indicates good discriminative ability.9, 10 If the c-statistic was not reported, we abstracted other operational statistics such as sensitivity, specificity and predictive values for representative risk score cut-offs when available. Model calibration is the degree to which predicted rates are similar to those observed in the population. To describe model calibration we report the range of observed readmission rates from the predicted lowest to highest risk groupings.

To guide our methodologic assessment of included studies, we adapted elements – including cohort definition, follow-up, adequacy of prognostic and outcome variable measurement, and validation method – from a prognosis study quality tool and clinical decision rule assessment tool (Appendix C).6, 11

## DATA SYNTHESIS

The included studies were too heterogenous to permit meta-analysis. Therefore, we qualitatively synthesized results, focusing on model discrimination, the populations in which the model has been tested, practical aspects of model implementation, and the types of variables included in each model.