# STUDY QUALITY ASSESSMENT CRITERIA

Study, year | Adequate description of population^*^ | Non-biased selection^†^ | Low loss to followup^‡^ | Adequate prognostic factor measurement^§^ | Adequate outcome measurement^‖^ | Method of validation
Amarasingham, 2010^24^ | Yes | Unsure (appears to be consecutive series but does not explicitly state this) | Unsure (did not report follow-up) | Yes | Yes | Derived and validated in same population using cross-validation metholodogy (75% derivation, 25% validation repeated 1000 times)
Anderson, 1985^22^ | No (good description of inclusion system but no description of overall demographics) | Yes | Unsure (did not report follow-up) | No (several prognostic factors not clearly described) | No, included interhospital transfers and did not exclude deaths | Different large cohort
Billings, 2007^25^ | Partly | Yes | Unsure | Yes | Partly - unclear if transfers and elective readmissions were excluded. | Split sample in a large cohort
Bottle, 2006^12^ | Yes | Yes | Yes | Partly - unsure how accurate geographic deprivation scores are | Partly - unclear if transfers and elective readmissions were excluded. | Split sample in a large cohort
Burns, 1991^58^ | Yes | Yes | Yes | Yes | Partly - unlikely that readmissions to other hospitals were captured | Split sample in a small cohort
CMS model, AMI Krumholz 2008^16^ | Yes | Yes | Unsure | Yes | Yes | Split sample in a large cohort
CMS model, CHF Krumholz, 2008^15^ | Yes | Yes | Partly (they excluded the 11% of patients for whom incomplete information was available) | Yes | Yes | Split sample in a large cohort
CMS model, Pneumonia Krumholz, 2008^17^ | Yes | Yes | Unsure | Yes | Yes | Split sample in a large cohort
Coleman, 2004^27^ | Yes | Yes | Partly - use of Medicare data ensures good degree of f/u, but data on transfers to skilled nursing facilities from home not readily available | Yes | Partly - outcome was complicated care transitions which included admission to skilled nursing facility from home. Not clear that such transfers were reliably identified using available datasets | Different large cohorts
Evans, 1988^59^ | Partly - inclusion criteria not well defined. | Unsure (probably consecutive series) | Unsure | Yes | Partly - outcome combined hospital readmissions, skilled nursing transfer from hospital, and stay longer than mean expected for DRG. It is unclear how valid the use of this combined measure is. Not clear that elective readmissions and transfers were excluded. | Split sample in a small cohort
Halfon, 2006^13^ | Yes | Yes | Unsure | Yes | Yes | Split sample in a large cohort
Hammill 2011^18^ | Yes | Yes | Unsure | Yes | Partly – 20% of registry patient files could not be linked to Medicare claims data and, therefore, is not included in outcome determination | Bootstrapping in large cohort
Hasan, 2009^31^ | Yes | Partly - large # excluded because they did not complete intake interview, mostly because they were discharged before they could be interviewed. Sample therefore will be skewed towards longer LOS patients | Unsure - # completing 30 D f/u to gather self-report utilization data unclear | Yes | Partly - readmissions to non-index hospitalization based on self-report and therefore subject to recall bias. Elective readmissions were included | Split sample in a large cohort
Holloway, 1990^53^ | Partly (validation cohort not clearly described) | Yes | Yes | Yes | Yes | Split sample in a large cohort
Holman, 2005^14^ | Yes | Yes | Yes | Partly - well-described methods, but administrative data only and comorbidity variables could have captured complications rather than comorbidities. No mention of effort to validate administrative data against chart review data. | Yes | Split sample in a large cohort
Howell, 2009^54^ | Yes | Yes | Yes | Yes | Partly - unclear how transfers were handled | Split sample in a large cohort
Krumholz, 2000^30^ | Yes | Yes | Unsure | Yes | Partly - readmissions from state-specific HCFA database - cross-state readmissions wouldn't be captured | Different large cohorts
Morrissey, 2003^28^ | Yes | Yes | Unsure | Partly - data based on medical chart review, but unclear how well certain factors such as smoking history were documented in the medical record | Partly - readmissions to other facilities were not captured, but it was a rural area and there were few other options for care | Different small cohorts
Naessens, 1992^23^ | Yes | Yes | Unsure | Yes | Yes | Jackknife approach using portions of large cohort
Novotny, 2008^33^ | Partly - exclusion included life expectancy < 6 months but it is unclear how this was determined. | Partly - consecutive patients but large # not reached before discharge and large # refused participation, many because they did not feel well and this could have skewed sample. | Yes | Yes | Partly - not clear that elective readmissions were excluded | Moderate size validation cohort only (validation of a previously derived instrument)
PARR model Billings, 2006^26^ | Partly | Yes | Unsure | Unsure | Partly - unclear if transfers and elective readmissions were excluded. | Split sample in a large cohort
Philbin, 1999^19^ | Yes | Yes | Unsure (did not report % of patients with outcome available, mean “follow-up” 6.9 months) | Partly - calendar year readmissions used as outcome and f/u interval was not included as a covariate | Partly (used calendar year readmissions rather than 12 months follow-up period, making admissions later in year less applicable. And, cross-state readmissions not captured) | Split sample in a large cohort
PRA (original) Boult, 1993^32^ | Yes | Yes | Partly (21.9% of patient records were not available through the end of 1988 and thus were excluded, but a selectively corrected two stage probit model no common influence between likelihood of missing data and readmission) | Yes | Yes | Split sample in a large cohort
PRA validation Allaudeen, 2011^34^ | Yes | Partly - enrolled patients and provider participants over only a 5 week period | Partly - unclear how many patients were contacted successfully for self-report utilization measure | Yes | Yes | Validation of a previously derived instrument (PRA)
Silverstein, 2008^20^ | Yes | Yes | Unsure (did not report) | Partly (comorbidities only assessed via discharge ICD-9 coding, not via actual measurement methods/scales) | Partly (only included readmission to Baylor MC, not to outside facilities) | Split sample in a large cohort
Smith Index (original) Smith 1985^55^ | Yes | Yes | Yes | Yes | Yes | Split sample in a small cohort
Smith Index validation Smith 1988^56^ | Yes | Yes | Unsure | Yes | Partly - a single center study and unclear how well readmissions to outside hospitals were captured | Validation of a previously derived instrument
Smith Index validation Smith, 1996^57^ | Partly - one of the criteria was expectation that pt would live > 3 months, but unclear how this was determined and how many pts were excluded for this reason | Partly - consecutive patients, but 20% could not be reached before discharge and another 20% declined to participate. Characteristics of these pts “were similar”. | Unsure | Yes | Yes | Bootstrapping in a small cohort
Thomas, 1996^21^ | No | Yes | Unsure | Partly - unclear how severity and complexity variables were calculated | Yes | different cohort (unsure of size)
van Walraven, 2010 29 | Yes | Yes | Yes, follow-up on 95.6% of population | Yes | Partly - outcome was self-report. Readmissions were considered unplanned if not arranged when patient had been discharged from index hospitalization. | Different large cohort

* Study describes inclusion criteria for selecting patients, and for enrolled patients describes duration and severity of symptoms, demographics (at least age), and setting (primary care vs. occupational vs. other).

† Study either reports enrolling (or attempting to enroll) a consecutive series of patients meeting inclusion criteria, or a random sample.

‡ Data for at least one outcome available for at least 80% of patients at 6 months or later of follow-up.

§ Study describes reproducible and appropriate methods for measuring prognostic factors.

‖ Study describes reproducible and appropriate methods to define and identify readmission; transfers and deaths during index hospitalization were excluded.