# INCLUSION/EXCLUSION CRITERIA FOR REVIEW OF FULL-TEXT ARTICLES

1. Is the full text of the article in English?
Yes | Proceed to #2
No | Code X1. STOP
2. Does the study population include adult patients admitted to a medical service?
Yes | Proceed to #3
No | Code X2. STOP
3. Is the article a primary study that develops or tests prediction models for risk of hospital readmission?
Yes | Proceed to #4
No | Code X3. Proceed to #5
4. Is the model tested in both a derivation and validation cohort, or is it a validation of a previously developed model?
Yes | Code I4. Proceed to #6
No | Code X4. Proceed to #6
5. Is the article a systematic review or meta-analysis of prediction models for risk of hospital readmission?
Yes | Code X5. Proceed to #6
(Eligible primary studies identified in systematic reviews will be coded I4).
No | Proceed to #6
6. If article meets none of the above criteria but may be useful for background/discussion, add code “B.”

Population: Adult patients admitted to a medical service. Post-surgical patients and psychiatric re-admissions are excluded.

Intervention: Risk prediction models derived and validated in a cohort of medical inpatients.

Comparator: Studies comparing the performance of two or more risk prediction models in a population will be included.

Outcomes: Hospital readmission – including all-cause readmissions, condition-specific readmissions, and potentially preventable readmissions. Readmission of inpatients to ICU is excluded.

Timing: No restrictions.

Setting: Exclude studies conducted in health systems of developing nations.