# SEARCH STRATEGY

Databases: Ovid Medline(R) 1996 to June 3 2010/Ovid Medline(R) and Ovid OLDMEDLINE(r) 1948 to June Week 3 2010/Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations Initial search: June 24, 2010 Update search: March 31, 2011
# | Searches | Results
1 | exp Patient Readmission/ | 5473
2 | readmi$.mp. | 12202
3 | rehosp$.mp. | 2507
4 | 1 or 2 or 3 | 13761
5 | exp Risk/ | 620133
6 | model$.mp. | 1748945
7 | predict$.mp. | 693749
8 | risk$.mp. | 1163956
9 | util$.mp. | 380641
10 | 5 or 6 or 7 or 8 or 9 | 3398624
11 | 4 and 10 | 5897
12 | “smith index”.mp. | 3
13 | “Probability of Repeated Admissions”.mp. | 1
14 | 11 or 12 or 13 | 5901
15 | limit 14 to “all adult (19 plus years)” | 4095
16 | remove duplicates from 15 | 4001
| Update search additional yield | 558

Databases: Cochrane Central Trial Registry (CCTR)/Cochrane Database of Systematic Reviews (CDSR)/Database of Abstracts of Reviews of Effectiveness (DARE) Searched: June 24, 2010 Update search: March 31, 2011
# | Searches | Results
1 | exp Patient Readmission/ | 401
2 | readmi$.mp. | 1478
3 | rehosp$.mp. | 523
4 | 1 or 2 or 3 | 1857
5 | exp Risk/ | 18547
6 | model$.mp. | 37010
7 | predict$.mp. | 28433
8 | risk$.mp. | 63301
9 | util$.mp. | 13015
10 | 5 or 6 or 7 or 8 or 9 | 112650
11 | 4 and 10 | 975
12 | “smith index”.mp. | 0
13 | “Probability of Repeated Admissions”.mp. | 0
14 | 11 or 12 or 13 | 975
After deduplication with previous search 960 unique citations
Update search additional yield: 137

Database: EMBASE Date: August 29, 2011
# | Searches | Results
1 | ‘hospital readmission’/exp | 7,965
2 | readmi* AND [embase]/lim | 13,680
3 | rehosp* AND [embase]/lim | 2,913
4 | #1 OR #2 OR #3 | 17,205
5 | ‘risk’/exp | 1,050,898
6 | model* AND [embase]/lim | 1,786,265
7 | predict* AND [embase]/lim | 920,849
8 | risk* AND [embase]/lim | 1,496,969
9 | util* AND [embase]/lim | 502,028
10 | #5 OR #6 OR #7 OR #8 OR #9 | 4,175,899
11 | #4 AND #10 | 7,846
12 | ‘smith index’ AND [embase]/lim | 3
13 | ‘probability of repeated admissions’ | 1
14 | #11 OR #12 OR #13 | 7,850
15 | #11 OR #12 OR #13 AND ([adult]/lim OR [aged]/lim) | 4,185
after deduplication with previous searches 1358 unique citations

Database: CINAHL Plus with Full Text 1986 - 2010 Initial search: June 24, 2010 Update search: March 31, 2011
Search ID# | Search Terms | Search Options | Results
S21 | #S16 NOT #S20 | Search modes - Boolean/Phrase | 122
S20 | S13 or S14 or S18 | Narrow by SubjectAge3: - Aged, 80 and over Narrow by SubjectAge2: - Adult: 19-44 years Narrow by SubjectAge1: - Middle Aged: 45-64 years Narrow by SubjectAge0: - Aged: 65+ years Search modes - Boolean/Phrase | 1024
S19 | S13 or S14 or S18 | Search modes - Boolean/Phrase | 1789
S18 | S11 and S17 | Search modes - Boolean/Phrase | 1789
S17 | S1 or S2 | Search modes - Boolean/Phrase | 3606
S16 | S12 or S13 or S14 | Narrow by SubjectAge3: - Aged, 80 and over Narrow by SubjectAge2: - Adult: 19-44 years Narrow by SubjectAge1: - Middle Aged: 45-64 years Narrow by SubjectAge0: - Aged: 65+ years Search modes - Boolean/Phrase | 1146
S15 | S12 or S13 or S14 | Search modes - Boolean/Phrase | 2013
S14 | “probability of repeated admissions” | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 1
S13 | “smith index” | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 0
S12 | S4 and S11 | Search modes - Boolean/Phrase | 2013
S11 | S5 or S6 or S7 or S8 or S9 or S10 | Search modes - Boolean/Phrase | 501973
S10 | util* | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 108769
S9 | risk* | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 259597
S8 | predict* | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 87796
S7 | “model*” | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 149297
S6 | (MH “Risk Factors”) | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 55640
S5 | (MH “Risk Assessment”) | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 27742
S4 | S1 or S2 or S3 | Search modes - Boolean/Phrase | 3959
S3 | rehosp* | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 684
S2 | readmi* | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean/Phrase | 3606
S1 | (MH “Readmission”) | Limiters - Published Date from: 19860101-20100631 Search modes - Boolean /Phrase | 2514
Update search additional yield | | | 122