# SUMMARY AND DISCUSSION

## LIMITATIONS

### PUBLICATION BIAS

Publication bias refers to the lack of publication of studies based on their findings. In its traditional sense, it refers to lack of publication of studies failing to show a statistically significant benefit for an intervention, or because journals are less likely to publish studies that reach null results. In this context, it is not clear whether the specific directionality of a comparison of quality of care between VA and non-VA facilities would lead authors or journal editors to not publish a study. So the potential for publication bias, while always a concern in any systematic review, is not qualitatively the same for this review as in reviews of medical interventions.

However, there is still concern that we identified all published studies of VA care compared to non-VA care. We searched broadly using a literature search strategy designed to identify such articles, but there is never any guarantee that all relevant studies have been found. The consistency of our findings, though, means that any studies that are unpublished would have to be both numerous and have results contrary to the published studies in order to substantively influence our conclusions.

### STUDY QUALITY

An important limitation common to systematic reviews is the quality of the original studies. We defined a minimum threshold of design and execution that must have been present for inclusion in our review. Criteria considered included the time frames of the quality measurement in VA and non-VA samples, the similarity of the measures of quality in both samples, the types of measures used, and the statistical methods. Above this threshold, we distinguished between studies based on a global assessment of quality. However, other factors not considered may also have influenced the results of studies in ways we cannot account for.

Ten of the seventeen articles included from the surgical literature were part of the Patient Safety in Surgery Study briefly described previously that used NSQIP methodology to compare care that was provided in the VA setting with that provided in 14 private sector, university hospitals9, 11–17, 19, 21. The NSQIP is the first validated, risk adjusted program evaluating outcomes and allowing for measurement of quality of care across surgical settings62. However, there are some potential limitations to the Patient Safety in Surgery Study that should be acknowledged. The 14 private sector hospitals in this study may not be generalizable to the private sector at large. Risk adjusted outcomes were assessed in most cases with stepwise logistic regression evaluating the impact of all variables collected on postoperative morbidity and mortality. A potential limitation includes omitted variable bias. For example, risk adjustment models were not able to account for stage of disease in the oncology studies or for indications for surgery in a number of other studies such as those evaluating outcomes after hepatectomy, adrenalectomy, thyroidectomy or parathyroidectomy. The omission of cases may have affected the findings in some studies, as well. For example, in the vascular surgery analyses, endovascular procedures performed outside of the operating room, such as in a radiology suite, were not accounted for. Additionally, in Hall et al’s study on thyroidectomies and parathyroidectomies, surgeries performed by otolaryngologists were not captured in the private sector data although they accounted for up to 50% of the operations in the VA12. Another limitation was inability to account for specific structural components of the care delivery system. For example, in the Lancaster paper assessing hepatectomy outcomes, the data did not take into account if the hospital had a transplant program, if they were able to perform veno-veno bypass, whether or not specialists in hepatology were on staff and available, ability to perform radiofrequency ablation or the quality of the intensive care units16. Finally, morbidity analyses across these studies were based on standard NSQIP assessment of morbidity. Disease and procedure specific outcomes could not be assessed with this data in some instances such as leak rate after pancreatectomy11, nerve injury after thyroidectomy or parathyroidectomy12, or disease recurrence after oncologic surgery11, 19.

An additional limitation is that all but one of the studies was either supported by VA research funding or had VA investigators performing some or all of the work. This may be natural as the VA has more interest than non-VA systems in comparing VA care with non-VA care. However, the possibility of bias must still be kept in mind.

Yet an additional limitation of the non-surgical comparisons is that they are either a narrow set of quality measures applied to a broad set of patients, or a broad set of quality measures applied to a limited sample of patients. In other words, for medical conditions, there is no study that assesses a broad set of quality measures on a national sample of patients. However, the results from the narrow-measures-broad-sample studies and the broad-measures-narrow-sample studies support each other, lessening the likelihood that a broad set of measures applied to a national sample of patients would yield results different from what we report here. Other limitations include lack of comparisons using data collected within the past five years, the use of self-reported data which may be subject to recall error, and the potential for inadequate assessment of clinical risk in studies comparing patient outcomes.

## CONCLUSIONS

With the above caveats in mind, we reached the following conclusions for the fifty five articles included in our synthesis. The seventeen surgery articles addressed a variety of conditions and procedures. Primary measures of quality tended to be outcomes measures such as morbidity, mortality, graft survival and occurrence of adverse events. The findings among these seventeen studies were heterogeneous with nine studies reporting no significant difference in quality outcomes, three studies reporting improved quality in the VA compared with the non-VA setting and five reporting improved quality in the non-VA setting. The majority of the surgical studies were based on the Patient Safety in Surgery Study.

Of four general surgery studies, three revealed no significant difference in adjusted postoperative morbidity rates; one found significantly lower rates of postoperative morbidity in the VA setting compared with the private sector. Only 3 of the 4 studies assessed risk adjusted mortality rates; of these two found no significant difference across settings and one found significantly higher risk adjusted rates of postoperative mortality among male patients at the VA compared with the private sector.

Of three solid organ transplant articles, two found no significant difference in patient survival when comparing VA patients with non-VA patients. Additionally, one of these found no significant different in graft survival between these two groups. This study also included a sub-analysis of HRQOL among heart and liver transplant recipients and found no significant different in functional status or mental component scoring, but noted a trend toward lower physical component scores among VA patients after 7 years post-transplant. One study found that VA patients with end-stage renal disease were both less likely to be listed for a kidney transplant and less likely to receive a transplant when listed compared with privately insured patients.

Two of the three vascular surgery studies found significantly lower risk adjusted rates of postoperative morbidity; the final vascular surgery study found no significant difference in morbidity rates. There were no significant differences in risk adjusted mortality rates throughout these three studies.

The studies pertaining to surgical oncology consisted of two that focused on pancreatic cancer and one that focused on breast cancer. One of the pancreatic cancer studies based on the NCDB found no significant difference in postoperative mortality. The other study on pancreatic cancer based on the Patient Safety in Surgery Study found increased risk adjusted postoperative rates of morbidity and mortality. The breast cancer study found no significant difference in risk adjusted postoperative morbidity.

Of the two studies that addressed quality of care related to CABG in VA and non-VA hospitals, one found that, after risk adjustment, VA patients were more likely than non-VA patients to report a problem with patient care. This was based on self-reported data about many aspects of patient care. The second study focused on mortality and found that the odds of death was higher in VA patients relative to private sector patients after accounting for patient level predictors and hospital volume.

In both of the endocrine studies, there were no significant differences in postoperative morbidity or adverse events.

Of 10 general comparative studies assessing use of preventive services, acute and chronic care for multiple medical acute and chronic medical conditions, changes in broad health status including risk-adjusted morality, and patient satisfaction, each showed superior performance, as measured by greater adherence to accepted processes of care, better health outcomes or improved patient ratings of care, for care delivered in the VA compared with care delivered outside the VA. Of the 6 studies that assessed cardiovascular outcomes, 5 studies of mortality following an acute myocardial infarction or percutaneous coronary transluminal angioplasty found no clear survival differences between VA and non-VA settings and one study found greater control of blood pressure in the VA. Of the 3 studies that assessed use of processes of care following an acute myocardial infarction, all three found greater rates of evidence-based drug therapy in VA, but one study found lower use of clinically-appropriate angiography in the VA. Four studies of the quality of diabetes care demonstrate a performance advantage on some measures for the VA compared with commercial managed care and other non-VA populations.

Studies of the quality of hospital and nursing home care demonstrate similar risk-adjusted mortality rates in VA facilities compared with non-VA facilities. VA hospitals had somewhat better patient safety outcomes compared with non-VA hospitals. Veterans in VA nursing homes were less likely to develop a pressure ulcer but more likely to experience functional decline compared to veterans in community nursing homes. In addition, the VA had higher use of infection control practices, but greater readmission rates and equivalent mortality rates across racial groups. Studies of the quality of mental health care demonstrate that the quality of antidepressant prescribing is slightly better in VA compared to private sector settings. One study of national data found VA patients with schizophrenia were more likely to receive an antipsychotic medication in the outpatient setting, but a study of data from two states found VA outpatients were less likely to receive an antipsychotic medication and psychosocial services. Among patients discharged after a hospitalization for schizophrenia, readmission and outpatient visit follow-up rates were worse in the VA, but continuity of care was better compared to the private sector.

Elderly VA patients are less likely to be prescribed potentially inappropriate medications than elderly patients in Medicare managed care plans. A study of survival following a diagnosis of lung carcinoma in Pennsylvania found worse survival for VA patients in that state. Stroke patients receiving rehabilitation in VA settings were discharged with better functional outcomes. VA patients had greater satisfaction with hearing aid fittings and somewhat greater self-reported benefit from hearing aid placement.

Of note, some of the studies compare a narrow band of practice(s), such as vaccinations or a specific type of surgery, across a broader population and other studies compare a wide spectrum of practices in a smaller sample (e.g., Asch et al.)23. Moreover, many of the studies are quite dated, with 16 articles using data prior to 2000, and more than likely practices have changed over time inside and outside of the VA.

Overall, the available literature suggests that the care provided in the VA compares favorably to non-VA care systems, albeit with some caveats. Studies that used accepted process of care measures and intermediate outcome measures, such as control of blood pressure or hemoglobin A1c, for quality measurements almost always found VA performed better than non-VA comparison groups. Studies looking at risk-adjusted outcomes generally have found no differences between VA and non-VA care, with some reports of better outcomes in VA and a few reports of worse outcomes in VA, compared to non-VA care. The studies of processes of care are mostly those about medical conditions, while the studies of outcomes are mostly about surgical conditions.

## FUTURE RESEARCH

Going forward, further research should be considered to address contemporary comparisons in the quality of care between the VA and the private sector. For example, most of the studies that compared the quality of surgical care in the VA with that in non-VA settings are based on data that is over five years old. The ACS-NSQIP has grown substantially from the original demonstration group of 14 university hospitals in the Patient Safety in Surgery Study to over 180 non-VA hospitals today. The data management for the ACS-NSQIP program has advanced, as well, with more surgical specialties being evaluated and with continually evolving data-fields for collection allowing for more detailed analysis. To further address the quality of care in the VA and non-VA settings, it may be worthwhile to repeat some of these studies using this larger sample; and consideration could be given to merging the VA and ACS NSQIP systems to allow for ongoing comparisons at the institutional and systems level. In areas of medical care, many studies are, as noted with the surgical literature, limited by their age, and newer projects would be worthwhile if benchmarking is considered important. If so, consideration should also be given to determining which healthcare systems the VA should benchmark against (e.g., other managed care organizations, local centers of excellence).