# RESULTS

## LITERATURE FLOW

In total, we examined 222 articles, from the “VHA Clinical Quality and Patient Safety: A review of the medical literature” and our second systematic literature search.

Of the titles identified in the review, 47 articles were rejected as duplicates. This left 175 articles to be screened.

From this initial screening, 98 articles were rejected because there was no comparison of quality in VA and US non-VA settings. Four more articles were rejected for falling before the cutoff date of 1990. Our data abstraction thus included 73 articles, 18 of which were rejected, having received a grade of C or having failed to meet the initial inclusion criteria upon further inspection.

Upon categorization, these final 55 articles were divided between surgical articles (n=17) and non-surgical/medical articles (n=38). Within the surgical category, there were 4 general surgury, 3 vascular surgery, 3 oncologic surgery, 3 solid organ transplantation, 2 cardiac surgery, and 2 endocrine articles. Within the medical category there were 10 general, 8 cardiovascular, 8 hospital care, 4 diabetes, 4 mental health care, and 4 other articles (See Figure 1).

Figure 1 Literature Flow

## DESCRIPTION OF EVIDENCE

We evaluated studies that compared quality of care for medical and surgical conditions in the Veterans Health Administration (VA) with clinical care in settings outside the VA. We summarize these data in the next two sections.

## SURGICAL CONDITIONS

We found 17 comparisons that met the inclusion criteria and pertained to the field of surgery6–22. Four of these addressed general surgery conditions9, 13, 16, 17, three addressed solid organ transplantation6, 10, 18, three addressed vascular surgery14, 15, 22, three addressed surgical oncology7, 11, 19, two addressed cardiac surgery8, 20, and two addressed endocrine surgery12, 21. Ten of the seventeen articles came out of the Patient Safety in Surgery Study which was performed from October 1, 2001 through September 30, 2004^9, 11–17, 19, 21^. The Patient Safety in Surgery Study grew out of collaboration between the American College of Surgeons and the VA, and aimed to determine if implementation of the National Surgical Quality Improvement Program (NSQIP) in the private sector could reduce postoperative mortality and morbidity in non-VA settings. This study compared risk adjusted postoperative morbidity and mortality for a number of general and vascular surgical conditions between the VA system and 14 university medical centers that had volunteered to be early adopters of NSQIP.

### GENERAL SURGERY

Four articles fell into the general surgery category9, 13, 16, 17; of these, two addressed general surgery broadly9, 13, one addressed liver resections16 and one addressed bariatric surgery17. All four of these articles were based on data from the Patient Safety in Surgery Study described above. The primary outcomes across studies were postoperative morbidity and mortality. Findings across these studies were heterogeneous.

Of the two broad general surgery papers, one focused on men and the other focused on women undergoing general surgery operations. Henderson and colleagues evaluated 94,098 general surgery operations in men at 128 VA medical centers and compared this with 18,399 general surgery operations in men in 14 university hospitals13. The main types of surgery performed were different in each population. Unadjusted postoperative morbidity and mortality rates were higher in the private sector compared with the VA. Stepwise logistic regression, adjusting for patient and disease characteristics, revealed no significant difference in postoperative morbidity across sites. However there were significantly greater odds of postoperative mortality in the VA (OR 1.23, 95% CI (1.08–1.41). Additional analysis revealed differences in unadjusted mortality rate by procedure type. Unadjusted mortality rates were comparable among the five most common general surgical operations performed in the VA and the private sector (open inguinal hernia, partial colectomy, laparoscopic cholecystectomy, umbilical hernia, ventral hernia), however unadjusted mortality rates were higher in the VA for less common, more complex operations (pancreatectomy, adrenalectomy, bariatric operation, thyroidectomy/parathyroidectomy and hepatectomy). Risk adjustments evaluated general surgery broadly and did not account for specific type of surgery.

Fink and colleagues reviewed 5,157 female patients in the VA and 27,367 female patients in the private sector who underwent general surgery operations during the Patient Safety in Surgery9. As in the study of male patients, certain procedures were performed more frequently in each of the two settings: more endocrine and laparoscopic procedures in the private sector and more lumpectomies and radical mastectomies in the VA. Unadjusted morbidity rates were higher in the private sector, likely attributable to the significantly higher incidence of urinary tract infections in this population. Unadjusted mortality rates were comparable across systems of care. After stepwise logistic regression to adjust for patient and disease characteristics there were significantly lower risk adjusted odds of developing a postoperative complication among the VA cohort compared with the private sector (OR 0.80, 95% CI 0.71–0.90); there was no significant difference in risk adjusted postoperative mortality among women undergoing general surgery operations. Risk adjustments evaluated general surgery broadly and did not account for specific type of surgery.

Lancaster and colleagues reviewed 237 VA and 783 private sector hepatectomies as part of the Patient Safety in Surgery Study16. Unadjusted morbidity and mortality rates were higher in the VA. After adjusting for pre-operative patient characteristics, lifestyle factors and intra-operative characteristics, morbidity and mortality rates were not significantly different between the VA and private sector university hospitals studied (morbidity 0.940, 95% CI 0.623–1.421 and mortality OR 1.623, 95% CI 0.609–4.324).

Lautz and colleagues evaluated 374 patients who underwent bariatric surgery in 12 VA hospitals and 2,064 patients who underwent bariatric surgery in the 12 private sector hospitals as part of the Patient Safety in Surgery Study17. Male and female VA patients were significantly more likely to undergo an open operation, had surgeries with higher mean relative value units and were hospitalized longer than private sector patients. Unadjusted morbidity and mortality rates were comparable in women across cohorts. After risk adjustment, there were still no significant differences in postoperative morbidity among women in the VA versus private sector. Unadjusted and adjusted morbidity rates were higher among men treated at the VA compared with the private sector (adjusted OR 2.99, 95% CI 1.28–4.10). Unadjusted mortality rates were significantly higher among men treated at the VA compared with the private sector. There were too few deaths to allow for determination of risk adjusted rates.

Summary: Of four general surgery studies, three revealed no significant differences in adjusted postoperative morbidity rates while one found significantly lower rates of postoperative morbidity in the VA setting compared with the private sector. Three of the 4 studies assessed risk adjusted mortality rates and of these, two found no significant difference across settings. One study found significantly higher risk adjusted rates of postoperative mortality among male patients at the VA compared with the private sector.

### SOLID ORGAN TRANSPLANTATION

Three articles addressed solid organ transplantation in VA and non-VA patients. Of these, one addressed orthotopic liver transplant only6, one addressed renal transplantation10, and one evaluated outcomes after liver, heart, renal and lung transplant18. Two studies compared survival. Of these, one evaluated mortality at one, three and five years post-OLT6, and one evaluated graft survival and patient survival after heart, lung, kidney and liver transplant18. The latter study also evaluated health related quality of life as a secondary outcome. The final study assessed differences in time to renal transplantation10.

Austin and colleagues studied 149 VA patients and 285 private sector patients who underwent orthotopic liver transplantation (OLT) at a single medical center between September 1991 and December 2000^6^. They aimed to determine whether there was a difference in mortality after OLT in US veterans compared with non-veterans and to evaluate what, if any, factors made a difference. Veterans received their pre and post transplant care at the Portland Veterans Affairs Medical Center (PVAMC) and non-Veterans received pre and post transplant care at the Oregon Health and Science University hospital; however, all patients were transplanted in the operating rooms of the VA and received initial postoperative intensive care at the VA. The outcome of interest was mortality at one, three and five years post transplant. Veterans had increased mortality rates as assessed by Kaplan-Meier curves. After adjusting for gender, donor age, recipient age, etiology of liver disease and MELD score, hospital status was not a significant predictor of mortality RR 1.15 (95% CI 0.94–1.43). In multivariate analysis, donor age was most predictive of survival. Austin et al found no significant difference between patient groups when evaluating time spent on the waiting list between evaluation and treatment. At the time of initial evaluation, patients who were veterans had lower average serum albumin levels and a higher percentage of patients with Child’s class C liver disease suggesting that perhaps veterans were referred later in the disease course. This study was limited in its retrospective nature, and in its inability to account for cause of death or account for pre transplant comorbidities. Additionally, use of the MELD score became standard during the course of the study, and thus the patient population included across this ten year time period may not be representative of patients who are eligible for or undergo transplant today. Due to missing data, 60 patients (43 university patients and 17 veterans) were excluded from the analyses. Five year survival was significantly different between the included and excluded patients overall (50% versus 73% respectively) potentially causing a bias in the results. Finally, this study was unable to account for post transplant substance abuse.

Moore et al were interested in comparing comprehensive outcomes in VA transplant patients compared with non-VA transplant patients18. They studied all adult patients from Vanderbilt University Medical Center and the VA Tennessee Valley Healthcare System who underwent a primary liver, kidney, heart or lung transplant between 1990 and 2002. All patients received heart, liver and lung transplants at VUMC; renal transplants were performed at both centers. VA patients received up to 3 months of postoperative care at VUMC prior to transfer back to the VA setting. Groups were distinguished primarily by payer status. Primary outcomes were graft survival and patient survival. Additionally, health related quality of life (HRQOL) was assessed in a subset of patients using Karnofsky functional performance and the SF-36. A total of 380 VA patients (141 liver, 54 heart, 183 kidney, 2 lung) were compared with 1,429 non-VA patients (280 liver, 246 heart, 749 kidney, 154 lung). Due to the limited number of lung transplant recipients, comparisons of outcomes were not performed in this subgroup. Cumulative graft survival was not significantly different between the two patient populations for liver transplant (p=0.97), heart transplant (p=0.67) or renal transplant (p=0.84). Similarly, cumulative patient survival was not significantly different between the two populations for liver (p=0.94, heart (p=0.75) or renal (p=0.12) transplant patients. HRQOL was assessed in a subset of 77 liver and 70 heart transplant recipients. Overall, there were significant improvements in functional performance from pre-transplant to 2 years post-transplant ((49+2 versus 90+2; (p<0.001. However, there was no significant difference in functional performance between VA and non-VA patients from the pre to post-transplant state (p=0.065). Additionally, there was no significant difference in functional performance between VA and non-VA patients at three (p=0.50) or seven years (p=0.17) post-transplant. SF-36 mental component scores measured post-transplant were not significantly different between the two patient populations. However, physical component scales diverged after 7 years post-transplant, with VA patients reporting slightly worse physical component scale (PCS) scores compared with non-VA patients (35+2 versus 39+1, p=0.05); mental component scale scores remained similar over time (47+2 versus 49+1, p=0.29 at 7 years post transplant). This study was limited in its cross sectional nature regarding HRQOL data; in addition, the patient populations were restricted to a single transplant program, potentially limiting the generalizability of the findings. Recurrence of hepatitis C and other patient level characteristics over time could not be taken into account, thus limiting ability to interpret the meaning behind the PCS scores long term. Additionally, the article does not make clear how the subset of heart and liver transplants was selected in order to evaluate HRQOL nor is the breakdown specified of VA and non-VA patients in this subset.

Gill et al used national data from the US Renal Data System from April 1, 1995 through December 31, 2004 to compare the time to transplantation among ESRD patients either covered by VA or insured by private insurance or Medicare/Medicaid10. A total of 7,395 VA patients were compared with 144,651 privately insured patients and an additional 357,345 insured by Medicare or Medicaid. After adjusting for patient demographics, clinical characteristics and state rates of transplantation, they found that VA-covered and Medicare/Medicaid-insured patients were approximately 35% less likely to receive transplants than patients with private insurance (hazard ratio [HR] 0.65; 95% CI 0.60 to 0.70; P < 0.0001). VA patients were less likely to be placed on the wait-list (HR 0.71; 95% CI 0.67 to 0.76). VA patients who were on the wait list also received transplants less frequently than privately insured patients (HR 0.89; 95% CI 0.82 to 0.96). VA patients with supplemental private insurance had the same likelihood of transplantation as non-VA patients with private insurance. Study limitations included unmeasured variables and inability to account for VA covered patients who had access to transplantation outside of the VA.

Summary: Of three solid organ transplant articles, two found no significant differences in patient survival when comparing VA patients with non-VA patients. Additionally, one of these found no significant difference in graft survival between these two groups. This study also included a sub-analysis of health related quality of life (HRQOL) among heart and liver transplant recipients and found no significant difference in functional status or mental component scoring, but noted a trend toward lower physical component scores among VA patients by 7 years post-transplant. One study found that compared with privately insured patients, VA patients with end-stage renal disease were both less likely to be listed for a kidney transplant and less likely to receive a transplant when listed.

### VASCULAR SURGERY

Three studies compared quality of care in the VA and the private sector in vascular surgery14, 15, 22. Two were from the Patient Safety in Surgery Study looking at male and female patients respectively14, 15. Hutter and colleagues evaluated 30,058 operations in men in the VA and 5174 in the private sector as part of the Patient Safety in Surgery Study14. The two populations had significantly different preoperative risk profiles. There were significantly different types and frequencies of vascular surgeries in the groups; for example, there were more carotid endarterectomies in the VA and more open abdominal aortic aneurysm repairs in the private sector. Unadjusted postoperative morbidity and mortality rates were higher in the private sector. After stepwise logistic regression adjusting for preoperative and intraoperative variables there was a significantly lower odds of perioperative complications in the VA (OR 0.84, 95% CI 0.78–0.92). There was no significant difference in risk adjusted mortality between the VA and private sector (p=0.195), although it was not clear how the relevant indicator variable for system of care was used in the model.

Johnson and colleagues used data from the Patient Safety in Surgery Study to compare 458 female VA patients and 3,535 non-VA female patients who underwent vascular surgery15. The two populations differed across many categories in assessing preoperative risk profile with private sector patients having a greater incidence of various preoperative morbidities. Private sector vascular operations were more likely to be emergencies. Types and frequencies of vascular surgery operations differed considerably across hospital type. For example VA patients had carotid endarterectomies, saphenous vein ligation and arteriovenous fistulas more commonly than private sector patients; private sector patients underwent above the knee amputations, femoral popliteal bypass with artificial graft material, femorotibial bypass and open abdominal aortic aneurysm more frequently than VA patients. Unadjusted postoperative morbidity and mortality were higher in the private sector. After stepwise logistic regression adjusting for patient and intra-operative characteristics, there was no significant difference in 30 day mortality rates among VA and PS female vascular patients; there was a significantly lower odds of experiencing a postoperative complication among VA patients compared with private sector patients (OR 0.60, 05 %CI 0.44–0.81). Both the Hutter and Johnson studies were unable to account for endovascular procedures performed outside the operating room (such as in the radiology or cardiology suites).

Weiss and colleagues evaluated perioperative mortality, stroke and cardiac complications in patients undergoing carotid endarterectomy in Connecticut from October 1997–September 22. VA data was derived from the Connecticut VA database that comprised data submitted to the VA-NSQIP. Private sector data was derived from the Connecticut Hospital Association database. They evaluated 140 carotid endarterectomies in the VA setting and 6,949 CEAs in the private sector. Based on a modified Charlson comorbidity score, patients in the VA had higher comorbidities than patients in the private sector. Unadjusted rates of mortality, stroke and cardiac complications were higher in the VA, though these differences were not significant. After adjusting for patient and disease characteristics, there were no significant differences in postoperative mortality, stroke or rate of cardiac complications. This study was limited by the small sample size and narrow geographic region and thus may not be generalizable to other VA or private sector settings. Additionally, the data sources were different for each cohort with VA data taken from NSQIP which includes chart abstraction while private sector data were derived from inpatient registries.

Summary: Of the three vascular surgery studies, two found significantly lower risk adjusted rates of postoperative morbidity in the VA and one found no significant difference in morbidity rates. There were no significant differences in risk adjusted mortality rates throughout these three studies.

### SURGICAL ONCOLOGY

Of the three articles on surgical oncology7, 11, 19, two focused on pancreatic cancer7, 11 and one focused on breast cancer19. The pancreatic cancer papers were derived from two data sources. Bilimoria and colleagues used the National Cancer Data Base (NCDB) to evaluate 513 VA patients, 12,576 academic hospital patients and 18,299 community hospital patients who underwent treatment for stage I and II pancreatic cancer from 1985–2004^7^. The cohorts differed significantly in the distributions of age, gender, race, disease stage, income, insurance and Charlson comorbidity score. The outcomes assessed included 60 day and 3 year mortality, as well as stage appropriate treatment including receipt of neoadjuvant therapy and resection. After adjusting for patient, surgical, disease and hospital characteristics, they found that mortality rates were comparable between the VA, academic and community hospital settings for resection of stage I and II pancreatic cancer. After risk adjustment, there was no difference in use of surgery or adjuvant chemotherapy between VA and academic hospitals (p=0.54), however VA hospitals were significantly more likely to use surgery and adjuvant chemotherapy than community hospitals (p<0.001). The use of NCDB only accounts for hospitals accredited by the American College of Surgeons Commission on Cancer thus there is a potential selection bias; additionally, this limits the generalizability of the findings to participating centers. Comorbidity data was only available through the NCDB starting in 2003, thus risk adjustment on patient characteristics was limited to the tail end of the study period. Finally, the reference group in the analyses was the VA which was also the smallest sample size.

The second article on pancreatic cancer was by Glasgow and colleagues; they used the Patient Safety in Surgery Study to compare postoperative morbidity and mortality after pancreatectomy for pancreatic cancer at 83 VA hospitals and 14 private sector hospitals11. Three hundred and seventy seven VA patients and 692 private sector patients were included. There were considerable differences in preoperative comorbidity profiles across cohorts. VA patients were less likely to be admitted from home and more likely to receive a blood transfusion intraoperatively. Using stepwise logistic regression to adjust for case mix differences, patient characteristics and intra-operative variables, they found higher rates of both 30 day postoperative morbidity (OR 1.58, 95% CI 1.08–2.31) and mortality (OR 2.53, 95% CI 1.02–2.38) in the VA compared with the private sector. These findings persisted after stratifying analyses by Whipple procedure or pancreaticoduodenectomy.

The final article pertaining to surgical oncology was done by Neumayer and colleagues as part of the Patient Safety in Surgery Study to compare postoperative morbidity from breast cancer surgery in the VA and private sector19. There were 644 VA patients and 3,179 private sector patients identified. The majority of the patients were female (n=3,634) and results were stratified by gender. Both male and female VA patients had more preoperative comorbidities, higher rates of mastectomy and higher unadjusted complication rates than their private sector counterparts. Stepwise logistic regression was done in the female cohort, adjusting for patient factors, disease characteristics, surgeon traits and type of surgery. There was no significant difference in risk adjusted 30 day morbidity between female patients in the VA and private sector (OR 1.40, 95% CI 0.89–2.20). Risk adjusted outcomes were not reported for the male cohort of breast cancer patients.

Summary: Of the three studies pertaining to surgical oncology, two focused on pancreatic cancer and one focused on breast cancer. One of the pancreatic cancer studies based on the National Cancer Data Base (NCDB) found no significant difference in postoperative mortality. The other study on pancreatic cancer based on the Patient Safety in Surgery Study found increased risk adjusted postoperative rates of morbidity and mortality in VA. The breast cancer study found no significant difference in risk adjusted postoperative morbidity among female patients. Two of the three surgical oncology studies came from the Patient Safety in Surgery Study (one pancreatic cancer study, one breast cancer study).

### CARDIAC SURGERY

Two articles pertained to cardiac surgery8, 20. Of these, one focused on patient perceptions of numerous aspects of patient care after coronary artery bypass grafting in VA and non-VA hospitals8. The second article compared severity adjusted mortality rates after CABG among VA and non-VA hospitals20.

Feria et al compared perceptions of aspects of patient care among male patients undergoing coronary artery bypass graft (CABG) in both VA and non-VA settings between 1995 and 1998^8^. The domains of patient care that were examined included respect for patient preferences, emotional support, patient education and communication, coordination of care, concern for physical comfort, family participation, transition to discharge, access, and courtesy. The VA sample consisted of 808 patients who underwent CABG at 43 VA hospitals. Perceptions were evaluated in postoperative surveys collected through the VA National Performance Feedback Center. The non-VA sample consisted of 2271 patients who underwent CABG at 102 non-VA hospitals. Data were extracted from routine postoperative surveys by the Picker Institute; hospitals were included only if they had contracted with the Picker Institute. After controlling for age, race, self-reported health status, and diagnosis related group, VA patients were more likely than non-VA patients to note a problem with patient care in 8 of the 9 dimensions with the exception of transition to discharge (p<0.001). Adjusted differences in the percentage of questions for which VA patients reported a problem relative to non-VA patients were significant in these 8 domains, including access (3.2, 95% CI 1.5–4.8), coordination of care (4.8, 95% CI 3.0–6.6), courtesy (2,9, 95% CI 1.4–4.5), patient education and information (7.1, 95% CI 4.4–9.8), emotional support (5.5, 95% CI 2.7–8.3), family participation (5.5, 95% CI 2.3–8.7), concern for physical comfort and(3.9, 95% CI 2.3–5.5) respect for patient preferences (6.2, 95% CI 3.6–8.7). A sub-analysis limited to teaching hospital settings found that VA patients remained more likely to note a problem with care in 5 dimensions including coordination of care, courtesy, patient education and information, emotional support and concern for physical comfort. Adjusted differences in percentage of questions for which VA patients reported a problem relative to non-VA patients were significant across 7 of the 9 dimensions of care including access (2.7, 95% CI 0.4–5.3), coordination of care (4.1, 95% CI 1.3–6.9), courtesy (2,3, 95% CI 0.5–4.2), patient education and information (6.0, 95% CI 2.9–9.1), emotional support (4.0 95% CI 0.9–7.1), concern for physical comfort and(3.0, 95% CI 1.2–4.8) respect for patient preferences (5.1, 95% CI 2.2–8.0). Limitations to this study included the many unmeasured variables, such as socioeconomic status, education level, literacy, patient autonomy in selecting providers, type and severity of comorbidities, emergency or elective surgery and hospital size and location. The non-VA sample was limited to hospitals contracting with the Picker Institute which accounted for only about 9% of US non-VA hospitals; the overall analysis was limited to a male population. Given these issues, the results may not be generalizable.

Rosenthal et al compared severity adjusted mortality after CABG among VA hospitals and private sector in two geographic regions between October 1993 and December 1996^20^. They studied 19,266 patients from 43 VA hospitals using data from the VA Continuous Improvement in Cardiac Surgery Program. An additional 44,247 patients from 32 New York state hospitals were studied using data from the New York State Cardiac Surgery Reporting System and 9,696 patients from 10 hospitals in the northeast Ohio were studied using data from the Cleveland Health Quality Choice. Each of these well established data sources contains slightly different information pertaining to patient and disease related traits; the VA CICSP contains about 90 components; the Cleveland Health Quality Choice collects about 250 items and the NY State Cardiac Surgery Reporting System collects data on 100 elements. VA patients were more likely to have congestive heart failure, chronic obstructive pulmonary disease, cerebrovascular disease, peripheral vascular disease and diabetes requiring medication than private sector patients. After adjusting for patient-level predictors and hospital volume, the study found that the odds of death were higher in VA patients than in private sector patients (OR, 1.34; 95% CI, 1.11–1.63; P <0.001). When comparing VA patients with those from NY State hospitals, a similar difference was found. However the comparison between VA and Northeast Ohio hospitals did not find a statistically significant difference in mortality rates. After stratifying by hospital volume, the odds of death among hospitals that performed 500 to 1000 CABG procedures annually were higher in VA hospitals than in private hospitals (OR 1.50, 95% CI 1.16–1.92, p=0.002) though this was not noted for lower CABG volumes (i.e., < 500) Limitations of this study included dependence on administrative data, unmeasured variable bias, potential systematic differences in data collection by the three data repositories used and geographic limitations to comparison groups potentially limiting generalizability of the findings. Additionally, the study period of 1993 to 1996 may not represent current outcomes or performance.

Summary: Two articles pertained to cardiac surgery. Of these, one focused on patient perceptions of numerous aspects of patient care after coronary artery bypass grafting in VA and non-VA hospitals. This study found that, after risk adjustment, VA patients were more likely than non-VA patients to report a problem with patient care. The second article compared severity adjusted mortality rates after CABG among VA and non-VA hospitals. After adjusting for patient-level predictors and hospital volume, the study found that the odds of death were higher in VA patients than in private sector patients.

### ENDOCRINE SURGERY

Two articles addressed issues in endocrine surgery12, 21. Each of these was from the Patient Safety in Surgery Study. One looked at 30 day postoperative morbidity and mortality after adrenalectomy21, the other looked at the same outcomes after thyroidectomy or parathyroidectomy12. Turrentine and colleagues evaluated 178 patients in 81 VA hospitals and 371 patients in 14 private sector hospitals who underwent adrenalectomy21. VA patients were more likely to be older, male and to have greater preoperative risk profiles. VA operations were less likely to be laparoscopic. Unadjusted morbidity and mortality rates were higher in the VA compared with the private sector, however after adjusting for patient characteristics (including demographics, comorbidities, lab values), provider characteristics and wound class, there was no significant difference in postoperative patients (OR 1.55, 95% CI 0.49–1.36). The mortality rate was too low for adjustment.

Hall and colleagues used the Patient Safety in Surgery Study to evaluate 2,814 VA patients and 4,268 patients in the private sector who underwent thyroidectomy or parathyroidectomy12. There were significantly different distributions of types of surgery at different sites with proportionally more parathyroid operations done at the VA. Unadjusted morbidity and mortality rates were significantly higher in the VA. Because the event rates for morbidity and mortality were very low, a combined variable was built for an outcome of ‘any adverse event’. Stepwise logistic regression evaluated adverse event rates, accounting for disease type, surgical specialty and patient characteristics. Risk adjusted adverse event rates did not differ significantly across sites (OR 1.25, 95% CI 0.87–1.78).

Summary: In both of the endocrine studies, there were no significant differences in postoperative morbidity or adverse event rates.

## MEDICAL AND OTHER NON-SURGICAL CONDITIONS

We identified 38 studies that compared quality of care for medical or other non-surgical conditions in the VA with clinical care in settings outside the VA23–54 26, 55–57 25, 27, 58–61. Of these, 10 studies (classified into a “general” category) assessed primary preventive services, multiple medical conditions, health status (including risk-adjusted mortality), or patient satisfaction 23, 28–30, 32, 40–42, 45, 46; 8 studies assessed cardiovascular conditions24, 34–36, 38, 47–49; 4 studies assessed diabetes31, 39, 50, 51; 8 studies assessed hospital and nursing home care33, 37, 43, 44, 53, 54, 60, 61; 4 studies assessed mental health care26, 55–57; and 4 studies assessed other conditions25, 27, 58, 59.

### GENERAL

We identified 3 studies of preventive services and all found substantially higher rates of influenza and pneumococcal vaccination for the elderly in the VA compared to samples drawn from outside the VA28, 30, 32. These studies rely on self-reported survey data from the Medicare Current Beneficiary Survey (MCBS) and the Behavioral Risk Factor Surveillance System (BRFSS). The MCBS, sponsored by the Centers for Medicare and Medicaid Services, is a survey of the health status, health care utilization, and demographic characteristics of a nationally-representative sample of aged, disabled, or institutionalized Medicare beneficiaries. The BRFSS, sponsored by the Centers for Disease Control and Prevention, is an annual state-based system of health surveys that collects information on the health risk behaviors, preventive health practices, and health care access of a nationally representative sample of nearly 350,000 adults.

Keyhani et al. used data from the 2000 to 2003 MCBS to examine use of pneumococcal and influenza vaccination and serum cholesterol screening among veterans age 65 and older using the VA exclusively compared to veterans age 65 and older using the Medicare fee-for-service and the Medicare managed care programs32. In this study, veterans using the VA reported 10% greater use of influenza vaccination (P< 0.05), 14% greater use of pneumococcal vaccination (P< 0.01), and a non-significant 6% greater use of serum cholesterol screening (P= 0.1), than did veterans receiving care through Medicare HMOs. Veterans receiving care through the Medicare fee-for-service program reported lower use of all three of these preventive services compared to veterans using the VA.

Jha et al. also assessed rates of vaccination using quality of care data abstracted from VA medical records among persons 65 and older in the VA compared to a similar age group of community-dwelling persons responding to the BRFSS30. Influenza and pneumonia vaccination rates were significantly greater in the VA compared to those reported in the BRFSS. In 2003, the absolute differences between the VA and the community based sample were approximately 10 percentage points for influenza vaccination and 30 percentage points for pneumococcal vaccination. The study was limited by non-equivalent methods of assessment of vaccination; chart review was used in the VA sample and self-report was used in the non-VA sample.

Finally, Chi et al used data from the 2003 BRFSS to assess influenza and pneumonia vaccination rates for veterans using the VA, veterans not using the VA, and non-veterans28. They found that for both influenza and pneumococcal vaccination, veterans using the VA had higher vaccination rates than both veterans not using the VA and non-veterans. Compared to veterans not using the VA, veterans using the VA had an 8 percentage point greater adjusted rate of receiving an influenza vaccination (72% vs. 80%, P < 0.001)) and a 17 percentage point greater rate of receiving pneumococcal vaccination (64% vs. 81%, P < 0.001)

We identified 3 studies that compared quality of care for multiple acute and chronic medical conditions23, 29, 40. Jha et al. compared quality of care in the VA and Medicare fee-for-service using 13 equivalent process of care measures29. The study assessed care for patients with diabetes, acute myocardial infarction, and congestive heart failure using data from the VA’s External Peer Review Program (EPRP), a previously published study of Medicare quality, and the Behavioral Risk Factor Surveillance System. The VA had statistically significant greater performance rates than the Medicare fee-for-service program on all 11 similar indicators from 1997 to 1999 and of 12 of 13 indicators in 2000. The exception was eye exams for patients with diabetes. In 2000, the VA equaled or exceeded 90% on 8 of 13 indicators while Medicare’s highest performance on any indicator was 84%.

Asch et al. assessed clinical performance on over 300 process of care indicators in a sample of 596 VA patients in 2 VISNs and a random sample of 992 adults from 12 communities that were selected to be representative of non-rural communities in the United States23. The authors found that, overall, VA patients were more likely than patients in the national sample to receive the care specified by the indicators (67% vs. 51%; difference, 16 percentage points [CI, 14 to 18 percentage points]). The VA outperformed the non-VA sample for both chronic care (72% vs. 59%; difference, 13 percentage points [CI, 10 to 17 percentage points]) and preventive care (64% vs. 44%; difference, 20 percentage points [CI, 12 to 28 percentage points]), but not for acute care. The biggest difference was in performance measures targeted by the VA (adjusted scores, 67% vs. 43%; difference, 24 percentage points [CI, 21 to 26 percentage points]).

Finally, Ross et al. compared self-reported use of 17 preventive services for cancer prevention, cardiovascular risk reduction, diabetes mellitus management, and infectious disease prevention among insured adults receiving and not receiving care in the VA40. The data were derived from the 2000 and 2004 BRFSS. The study found that in 2000, persons receiving VAMC care were more likely to receive 6 of the 17 services; in 2004, persons receiving VAMC care reported greater use of 12 of the 17 services. In 2004, the performance advantage for the VA among these 12 services ranged from 10% greater use of cholesterol screening to 40% greater use of colorectal cancer screening. In 2004, there were no services for which rates of use were significantly greater for insured populations outside the VA than for patients using the VA.

We identified 3 studies that assessed changes in risk adjusted mortality and health status for elderly VA patients compared to elderly patients enrolled in Medicare Advantage (MA) plans41, 42, 46. Selim et al. surveyed a cohort of VA and MA enrollees at baseline and then 2 years later using the Short Form 36, a validated measure of health status42. They also linked these surveys to the death master file to assess status. In analyses adjusting for demographic characteristics, clinical conditions, and baseline health status, MA enrollees had a greater risk of 2 year mortality compared to VA patients (9.2% vs. 7.5% HR 1.363 (95%CI 1.275–1.458). The adjusted probability of being alive with the same or better physical health after 2 years was similar in both systems. However, the VA cohort had a slightly higher adjusted probability of being alive with the same or better mental health score at 2 years (71.8% in the VA vs. 70.1% in MA). Using similar methods, another study by these authors extended the analysis to an approximately five year time frame, with similar results41. They found that risk-adjusted mortality rates over an approximately five year period was 26.0% for male VA patients and 28.8% for male Medicare Advantage patients (HR 1.404; 95% CI 1.383–1.426). Among female patients, the unadjusted mortality rates were 20.2% for the VA and 23.4% for the Medicare Advantage program (HR 1.244; 95%CI 1.168–1.324). In a separate analysis, the adjusted rate of 3 year mortality was higher for MA enrollees eligible for Medicaid than in VA enrollees eligible for Medicaid (HR, 1.260 [95% CI, 1.044–1.520])46.

Harada et al. examined patient satisfaction with outpatient care among VA users compared to non-users in southern California and southern Nevada45. VA users were 2 to 8 times more satisfied than VA non-users on 5 of 10 measures of satisfaction. VA users were less satisfied than non-VA users on one measure: the number of days waited for an appointment.

Summary: Of 10 general comparative studies assessing use of preventive services, acute and chronic care for multiple medical acute and chronic medical conditions, changes in broad health status including risk-adjusted morality, and patient satisfaction, each showed superior performance, as measured by greater adherence to accepted processes of care, better health outcomes or improved patient ratings of care, for care delivered in the VA compared with care delivered outside the VA. The studies used data from 1995 to 2004.

### CARDIOVASCULAR

We identified 8 studies that assessed quality of care for cardiovascular conditions24, 34–36, 38, 47–49. Three studies by Petersen et al. assessed risk-adjusted mortality rates, use of clinically-appropriate coronary angiography, and receipt of effective cardiovascular medications following an acute myocardial infarction among male enrollees in the Medicare fee-for-service program compared to elderly male veterans treated in VA facilities during 1994 and 1995^35, 47^. The authors studied 19,305 male Medicare beneficiaries hospitalized in 1530 nonfederal acute care hospitals for myocardial infarction and 1665 elderly male veterans with myocardial infarction who were treated in 81 VA medical centers. In analyses adjusting for demographic and clinical characteristics, the authors found no difference in mortality for Medicare patients compared with the VA at 30 days (OR 0.94, 95% CI 0.82–1.07) and at one year (OR 0.94, 95% CI 0.84–1.05). Patients in the VA were less likely to receive angiography when clinically needed (43.9 percent vs. 51.0 percent; odds ratio, 0.75; 95% CI, 0.57 to 0.96). After controlling for the availability of on-site cardiac procedures, there was no difference in the rate of angiography36.

Of the patients who survived their hospitalization, more VA patients than Medicare patients received beta-blockers (49.7 percent vs. 41.6 percent, P<0.001), angiotensin-converting-enzyme inhibitors (44.6 percent vs. 32.5 percent, P<0.001), or aspirin (77.2 percent vs. 68.6 percent, P<0.001) at discharge. Among a subset of patients deemed to be ideal recipients of these medications, VA patients were more likely than Medicare patients to undergo thrombolytic therapy at arrival (OR 1.40 [1.05, 1.74]) or to receive ACE inhibitors (OR 1.67 [1.12, 2.45]) or aspirin (OR 2.32 [1.81, 3.01]) at discharge and equally likely to receive beta-blockers (OR 1.09 [1.03, 1.40]) at discharge47.

Landrum et al. studied mortality following acute myocardial infarction for elderly male veterans hospitalized in the VA and a matched set of male Medicare beneficiaries treated in non-VA hospitals between 1996 and 1999^34^. The study found that in 1999 there were no significant differences in adjusted 30 day and one year mortality following myocardial infarction between the VA and Medicare. However, in earlier years of the study (1997 and 1998) there were higher adjusted mortality rates in the VA compared to Medicare.

Ritchie et al. compared 10 and 30 day mortality rates and use of cardiac bypass surgery among patients receiving percutaneous coronary angioplasties in a national sample of VA medical centers and a sample of private sector hospitals in the state of Washington48. In this study, mortality and bypass surgery rates were largely similar for patients treated in the VA and private sector.

Wright et al. examined mortality rates following an acute myocardial infarction for Medicare-eligible VA-users initially admitted to a VA medical center compared with VA users initially admitted to a Medicare-financed hospital49. There were no significant differences in 30 day and 1 year mortality rates for VA users initially admitted to VA medical centers compared to Medicare hospitals.

Another study by Bansal et al. of quality of care for acute myocardial infarction compared use of aspirin, beta-blockers, ace-inhibitors, heparin, and other specified anti-thrombotic agents among patients with an acute myocardial infraction in the Little Rock VA (n=117) compared to patients with acute myocardial infarction in a national sample derived from the National Registry of Myocardial Infarction 24. The study found higher use of all of these agents in patients at the Little Rock VA compared to those obtaining care elsewhere in Arkansas and to those in the national sample.

Finally, Rehman et al. studied rates of blood pressure control in VA compared to non-VA setting using data from the National Health and Nutrition Examination Survey (NHANES) from 1999 to 2000^38^. The NHANES is a survey of a nationally-representative sample of 5000 persons that is administered by the Centers for Disease Control and Prevention. The survey combines detailed demographic, socioeconomic, nutrition, and health-related questions with a physical examination and laboratory testing by trained medical personnel. The authors found that while blood pressure control to below 140/90 mmHg was comparable among white hypertensive men at VA (55.6%) and non-VA (54.2%) settings (P=.12), blood pressure control was higher among African American hypertensive men at VA (49.4%) compared with non-VA (44.0%) settings (P< 0.01), even after controlling for age, numerous co-morbid conditions, and rural-urban classification.

Summary: Of the 6 studies that assessed cardiovascular outcomes, 5 studies of mortality following an acute myocardial infarction or percutaneous coronary transluminal angioplasty found no clear survival differences between VA and non-VA settings and one study found greater control of blood pressure in the VA. Of the 3 studies that assessed use of processes of care following an acute myocardial infarction, all three found greater rates of evidence-based drug therapy in VA, and one study found lower use of clinically-appropriate angiography in the VA. Of note, all of these cardiovascular studies use data that are between 7 to 18 years old.

### DIABETES

We identified 4 studies that focused exclusively on comparing quality of care for diabetes in the VA and outside the VA31, 39, 50, 51. Kerr et al. compared clinical performance on 7 diabetes care processes, 3 diabetes intermediate outcomes, and 4 measure of patient satisfaction in 5 VA medical centers and in 8 commercial managed care organizations in matched geographic regions31. The study sample included 1285 patients in the VA and 6920 patients in commercial managed care plans. The VA outperformed commercial managed care plans on all measures of care processes. Intermediate outcome of blood pressure control was comparable between the two cohorts; however, the VA cohort had a significantly greater percentage of patients with tight blood sugar and cholesterol control. Patients reported similar overall satisfaction in the two cohorts, though there was significantly greater satisfaction with diabetes care in the VA.

Reiber et al. assessed use of preventive services among veterans with self-reported diabetes using the VA compared with diabetic veterans and non-veterans receiving care outside the VA39. The study sample included 535 veterans using VA care, 1848 veterans using non VA care and 9055 nonveterans responding to the 2000 BRFSS. The study found that veterans who used the VA had higher rates of foot exams, diabetes education, and sigmoidoscopy and a lower rate of a1c testing compared to veterans who did not use the VA. There were non-significant differences between these two groups in the receipt of eye exams, blood pressure measurements, cholesterol testing and fecal occult blood testing.

Nelson also examined 2000 BRFSS data and compared use of preventive services among VA enrollees with diabetes compared to persons with diabetes with other sources of insurance coverage50. The authors found that persons who received care through the VA were more likely to report taking a diabetes education class than those covered by private insurance The adjusted odds ratio for receipt of diabetes education among persons receiving all of their care through the VA was 3.5 (95% CI 1.6–7.8).

Piette studied satisfaction with care among patient with diabetes treated in 4 VA outpatient clinics compared with patients with diabetes receiving care in a 2 county-funded clinics51. The authors found that VA patients were more satisfied than were county patients overall and with 5 of 6 dimensions of their care. These dimensions include access, technical quality, communication, interpersonal care, and quality of outcomes.

Summary: Four studies of the quality of diabetes care demonstrate a performance advantage on some measures for the VA compared with commercial managed care and other non-VA populations.

### HOSPITAL AND NURSING HOME CARE

We identified 8 studies that compared the quality of hospital care in the VA with care outside the VA33, 37, 43, 44, 53, 54, 60, 61.

Polsky et al. examined racial differences in 30 day mortality for patients in VA and non-VA hospitals who were hospitalized for one of six conditions (pneumonia, congestive heart failure, gastrointestinal bleeding, hip fracture, stroke, or acute myocardial infarction)37. The data were derived from hospital discharge abstracts from California and Pennsylvania. The study found that among patients less than age 65 years, black patients in VA and non-VA hospitals had similar 30 day mortality rates to whites for gastrointestinal bleeding, hip fracture, and stroke. Among patients 65 years and older, blacks patients in VA and non-VA hospitals had significantly lower odds of 30 day mortality compared to white patients for all conditions except pneumonia. Racial mortality differences for these conditions were similar in VA and non-VA settings.

Weeks et al. compared readmission rates for hospitalized VA enrollees who received care in a VA hospital compared with rates for VA enrollees who were hospitalized in non-VA hospitals43. The study included 111,854 patients residing in New York State. Among persons less than age 65, there were no significant differences in 30 day readmission rates for veterans admitted to a VA hospital compared with veterans initially admitted to a non-VA hospital. However, for veterans 65 and older, persons initially admitted to a VA hospital had a significantly higher odds of readmission within 30 days than persons not initially admitted to a VA hospital (OR 2.79, 95%CI 1.4–5.6). In another similar study, Weeks et al. assessed 15 indicators of patient safety for inpatient care provided in VA hospitals compared to care provided outside the VA system44. The study found lower risk-adjusted rates of decubitus ulcer, postoperative sepsis, nosocomial infection, postoperative respiratory failure, and postoperative metabolic derangement for VA enrollees hospitalized in VA hospitals compared with rates among VA enrollees treated in hospitals outside the VA. The VA performed worse on one patient safety indicator: mortality rates for low-risk diagnoses. For 9 of the 15 patient and non-VA hospitals. safety indicators, there were no significant

Krein et al. assessed the use of central venous catheter bloodstream infection prevention practices in VA and non-VA hospitals using data from survey of a random sample of infection control coordinators in 516 hospitals33. The study found that compared with non-VA hospitals, VA hospitals reported greater use of maximal sterile barrier precautions, chlorhexidine gluconate for insertion site antisepsis, and a composite approach using multiple safety practices.

Three similar studies compared hospital mortality rates in a single VA medical center with moratlity rates in different samples of private sector hospitals53, 54, 61. Gordon et al. found no significant difference in adjusted mortality rates for the VA medical center compared to a national sample of non-VA hospitals53. The actual in-hospital mortality rate was 4.0%, compared with the predicted mortality rate based on the private sector sample of 4.4% (95%CI 4.0% – 4.9%)

Rosenthal also found that risk-adjusted in-hospital mortality was similar in the VA medical center compared with private sector hospitals in the same metropolitan area (OR 1.07 95%CI 0.74–1.54)60. Mortality among patients admitted to an intensive care unit was also similar in the VA medical center compared with hospitals in the same metropolitan area61.

Finally, Berlowitz examined risk-adjusted rates of pressure ulcer development, functional decline, behavioral decline, and mortality in VA nursing homes compared with community nursing homes54. Veterans in VA nursing homes were less likely to develop a pressure ulcer (OR 0.62 95%CI 0.47–0.83) but more likely to experience functional decline (OR 1.6 95%CI 1.2–2.1) compared to veterans in community nursing homes. Risk-adjusted mortality and rates of behavioral decline were not different for veterans in VA and community nursing homes.

Summary: Studies of the quality of hospital and nursing home care demonstrate similar risk-adjusted mortality rates in VA facilities compared with non-VA facilities. VA hospitals had somewhat better patient safety outcomes compared with non-VA hospitals. Veterans in VA nursing homes were less likely to develop a pressure ulcer but more likely to experience functional decline compared to veterans in community nursing homes. In addition, the VA had higher use of infection control practices, but greater readmission rates and equivalent mortality rates for racial minorities.

### MENTAL HEALTH

We identified 4 studies assessing the quality of mental health care in VA and non-VA settings26, 55–57. Busch et al. compared the quality of antidepressant pharmacotherapy in the VA and private sector using identical performance indicators26. The authors determined the proportion of patients with a new diagnosis of depression who received a prescription for an antidepressant and remained on antidepressant therapy for the first 84 days following the diagnosis (known as the acute phase of treatment) and for the first 181 days following the diagnosis (known as the maintenance phase of treatment). The VA slightly outperformed the private sector in the prescription of antidepressants during the acute phase of treatment (84.7 compared with 81 percent; p<0.001) and during the maintenance phase of treatment (53.9 compared with 50.9 percent; p<0.001). The findings persisted when assessed by age and gender.

Leslie et al. compared care for hospitalized patients with schizophrenia in the VA and private sector55. Rates of readmission were lower and rates of timely follow-up visits after discharge were higher in the private sector compared to the VA. The VA had better continuity of care, defined as the number of two-month periods in which the patient had two or more outpatient visits in the six months after discharge. In an analysis of the quality of antipsychotic prescribing among patients with schizophrenia, Leslie et al. found that VA patients were more likely to receive a prescription for an antipsychotic and equally likely to be dosed in accordance with accepted clinical guidelines compared to private sector patients with schizophrenia56.

Finally, Rosenheck examined adherence to 26 treatment guidelines recommended by the Patient Outcomes Research Team (PORT) for patients with schizophrenia57. In an analysis of care for patients with schizophrenia in two states in the southeast and Midwest, the study found non-significant differences in adherence to PORT recommendations between VA and non-VA patients for 21 of the 26 measures. Significant differences were found in the following areas: VA outpatients were less likely to receive an antipsychotic medication and to be taking doses outside of the recommended range; VA inpatients were less likely to receive treatment that addressed psychosocial issues than non-VA inpatients; VA outpatients were less likely to participate in work therapy or job training than non-VA outpatients, and both VA inpatients and outpatients were less likely to receive case management services than non-VA patients.

Summary: Studies of the quality of mental health care demonstrate that the quality of antidepressant prescribing is slightly better in VA compared to private sector settings. One study of national data found VA patients with schizophrenia were more likely to receive an antipsychotic medication in the outpatient setting, but a study of data from two states found VA outpatients were less likely to receive an antipsychotic medication and psychosocial services. Among patients discharged after a hospitalization for schizophrenia, readmission and timely outpatient visit follow-up rates after discharge were worse in the VA, but continuity of care in the outpatient setting was better compared to the private sector.

### OTHER STUDIES

We classified 4 additional studies into an ‘other’ category 25, 27, 58, 59.

Barnett et al. compared the use of potentially inappropriate medications among elderly patients in the VA and Medicare managed plans and 10 distinct geographic regions25. The authors identified 33 medications that in previously published studies have been generally considered inappropriate when given to the elderly because these medications may pose more risk than benefit. The 33 medications were classified into the following 3 categories: “always avoid”, “rarely appropriate” and “some indications’. Compared with Medicare managed care patients, VA patients were less likely to receive any inappropriate medication (21% vs. 29%, P <0.001), and in each classification: always avoid (2% vs. 5%, P <0.001), rarely appropriate (8% vs. 13%, P<0.001), and some indications (15% vs. 17%, P <0.001). The rate of inappropriate drug use was lower in the VA compared with the private sector for both males (21% vs. 24%, P <0.001) and females (28% vs. 32%, P <0.001). Differences were consistent when stratified by age.

Campling et al. examined the survival of Pennsylvania patients diagnosed with lung carcinoma between 1995 and 1999 who were treated in VA medical centers compared to patients treated in other medical centers in the state27. The median survival was 6.3 months for VA patients compared with 7.9 months for patients in the rest of the state, and the 5-year overall survival rate was 12% for VA patients compared with 15% for patients in the rest of the state. The Cox model showed a hazard ratio for VA patients compared with non-VA patients of 1.22 (P< 0.001) after adjusting for age, disease stage, and race, meaning that VA patients had a 22% greater odds of dying over the same time period.

Stineman studied functional outcomes following a stroke for patients admitted to 60 VA and 467 non-VA rehabilitation facilities58. Across 20 different types of functional impairments, VA patients had significantly better motor outcomes on 8 impairments and worse outcomes for 2 impairments compared to non-VA patients.

Cox et al. compared satisfaction with hearing aid fittings and perceived benefit from hearing aid placement among VA and non-VA patients59. VA patients reported greater satisfaction with the fitting of the hearing aid. Using three survey instruments to assess the perceived benefit of using the hearing aid in comparison to unaided hearing, VA patients reported greater benefit on all three instruments. In multivariate analysis of variance adjusting for baseline level of hearing loss, VA had significantly greater benefit from hearing aid placement on a composite measure of all three instruments. When the instruments were examined separately, VA patients reported greater benefit on one instrument but not the other two.

Summary: Elderly VA patients were less likely to be prescribed potentially inappropriate medications than elderly patients in Medicare managed care plans. A study of survival following a diagnosis of lung carcinoma in Pennsylvania found worse survival for VA patients in that state. Stroke patients receiving rehabilitation in VA settings were discharged with better functional outcomes. VA patients had greater satisfaction with hearing aid fittings and somewhat greater self-reported benefit from hearing aid placement.