# REFERENCES

1 Longman P. Best Care Anywhere: Why VA Health Care Is Better Than Yours. 2007. Sausalito. PoliPointPress.
2 Ashton CM, et al. Hospital use and survival among Veterans Affairs beneficiaries. N Engl J Med. 2003;349(17):1637-46. [pmid: 14573736].
3 Maslin J. March. 13. Article 99: Idealism Meets Iodine and Illogic in a Veterans Hospital. New York Times. 1992:99.
4 Canby V. December. 20. 1989. Born on the Fourth of July: How an All-American Boy Went to War and Lost His Faith. New York Times.
5 Bogdanich W. June. 29. 2009. Oncologist Defends His Work at a V. A. Hospital. New York Times.
6 Austin GL, et al. Comparative analysis of outcome following liver transplantation in US veterans. Am J Transplant. 2004;4(5):788-95. [pmid: 15084176].
7 Bilimoria KY, et al. Quality of pancreatic cancer care at Veterans Administration compared with non-Veterans Administration hospitals. Am J Surg. 2007;194(5):588-93. [pmid: 17936418].
8 Feria MI, Sarrazin MV, Rosenthal GE. Perceptions of care of patients undergoing coronary artery bypass surgery in Veterans Health Administration and private sector hospitals. Am J Med Qual. 2003;18(6):242-50. [pmid: 14717382].
9 Fink AS, et al. Comparison of risk-adjusted 30-day postoperative mortality and morbidity in Department of Veterans Affairs hospitals and selected university medical centers: general surgical operations in women. J Am Coll Surg. 2007;204(6):1127-36. [pmid: 17544071].
10 Gill JS, et al. Access to kidney transplantation among patients insured by the United States Department of Veterans Affairs. J Am Soc Nephrol. 2007;18(9):2592-9. [pmid: 17687075].
11 Glasgow RE, et al. Pancreatic resection in Veterans Affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;204(6):1252-60. [pmid: 17544083].
12 Hall BL, et al. Thyroid and parathyroid operations in veterans affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;204(6):1222-34. [pmid: 17544080].
13 Henderson WG, et al. Comparison of risk-adjusted 30-day postoperative mortality and morbidity in Department of Veterans Affairs hospitals and selected university medical centers: general surgical operations in men. J Am Coll Surg. 2007;204(6):1103-14. [pmid: 17544069].
14 Hutter MM, et al. Comparison of risk-adjusted 30-day postoperative mortality and morbidity in Department of Veterans Affairs hospitals and selected university medical centers: vascular surgical operations in men. J Am Coll Surg. 2007;204(6):1115-26. [pmid: 17544070].
15 Johnson RG, et al. Comparison of risk-adjusted 30-day postoperative mortality and morbidity in Department of Veterans Affairs hospitals and selected university medical centers: vascular surgical operations in women. J Am Coll Surg. 2007;204(6):1137-46. [pmid: 17544072].
16 Lancaster RT, et al. Liver resection in veterans affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;204(6):1242-51. [pmid: 17544082].
17 Lautz DB, et al. Bariatric operations in Veterans Affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;204(6):1261-72. [pmid: 17544084].
18 Moore D, et al. Survival and quality of life after organ transplantation in veterans and nonveterans. Am J Surg. 2003;186(5):476-80. [pmid: 14599610].
19 Neumayer L, et al. Breast cancer surgery in Veterans Affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;204(6):1235-41. [pmid: 17544081].
20 Rosenthal GE, Vaughan Sarrazin M, Hannan EL. In-hospital mortality following coronary artery bypass graft surgery in Veterans Health Administration and private sector hospitals. Med Care. 2003;41(4):522-35. [pmid: 12665716].
21 Turrentine FE, et al. Adrenalectomy in Veterans Affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;204(6):1273-83. [pmid: 17544085].
22 Weiss JS, et al. Safety of carotid endarterectomy in a high-risk population: lessons from the VA and Connecticut. J Am Coll Surg. 2006;203(3):277-82. [pmid: 16931298].
23 Asch SM, et al. Comparison of quality of care for patients in the Veterans Health Administration and patients in a national sample. Ann Intern Med. 2004;141(12):938-45. [pmid: 15611491].
24 Bansal D, et al. Trends in the care of patients with acute myocardial infarction at a university-affiliated Veterans Affairs Medical Center. J Cardiovasc Pharmacol Ther. 2005;10(1):39-44. [pmid: 15821837].
25 Barnett MJ, et al. Comparison of rates of potentially inappropriate medication use according to the Zhan criteria for VA versus private sector medicare HMOs. J Manag Care Pharm. 2006;12(5):362-70. [pmid: 16792442].
26 Busch SH, Leslie DL, Rosenheck RA. Comparing the quality of antidepressant pharmacotherapy in the Department of Veterans Affairs and the private sector. Psychiatr Serv. 2004;55(12):1386-91. [pmid: 15572566].
27 Campling BG, et al. A population-based study of lung carcinoma in Pennsylvania: comparison of Veterans Administration and civilian populations. Cancer. 2005;104(4):833-40. [pmid: 15973670].
28 Chi RC, Reiber GE, Neuzil KM. Influenza and pneumococcal vaccination in older veterans: results from the behavioral risk factor surveillance system. J Am Geriatr Soc. 2006;54(2):217-23. [pmid: 16460371].
29 Jha AK, et al. Effect of the transformation of the Veterans Affairs Health Care System on the quality of care. N Engl J Med. 2003;348(22):2218-27. [pmid: 12773650].
30 Jha AK, Wright SM, Perlin JB. Performance measures, vaccinations, and pneumonia rates among high-risk patients in Veterans Administration health care. Am J Public Health. 2007;97(12):2167-72. [pmid: 17971554].
31 Kerr EA, et al. Diabetes care quality in the Veterans Affairs Health Care System and commercial managed care: the TRIAD study. Ann Intern Med. 2004;141(4):272-81. [pmid: 15313743].
32 Keyhani S, et al. Use of preventive care by elderly male veterans receiving care through the Veterans Health Administration Medicare fee-for-service, and Medicare HMO plans. Am J Public Health. 2007;97(12):2179-85. [pmid: 17971544].
33 Krein SL, et al. Use of central venous catheter-related bloodstream infection prevention practices by US hospitals. Mayo Clin Proc. 2007;82(6):672-8. [pmid: 17550746].
34 Landrum MB, et al. Care following acute myocardial infarction in the Veterans Administration Medical Centers: a comparison with Medicare. Health Serv Res. 2004;39(6 Pt 1):1773-92. [pmid: 15533186].
35 Petersen LA, et al. Outcome of myocardial infarction in Veterans Health Administration patients as compared with medicare patients. N Engl J Med. 2000;343(26):1934-41. [pmid: 11136265].
36 Petersen LA, et al. Regionalization and the underuse of angiography in the Veterans Affairs Health Care System as compared with a fee-for-service system. N Engl J Med. 2003;348(22):2209-17. [pmid: 12773649].
37 Polsky D, et al. Is lower 30-day mortality posthospital admission among blacks unique to the Veterans Affairs health care system?. Med Care. 2007;45(11):1083-9. [pmid: 18049349].
38 Rehman SU, et al. Ethnic differences in blood pressure control among men at Veterans Affairs clinics and other health care sites. Arch Intern Med. 2005;165(9):1041-7. [pmid: 15883244].
39 Reiber GE, et al. Diabetes in nonveterans, veterans, and veterans receiving Department of Veterans Affairs health care. Diabetes Care. 2004;27(Suppl 2):B3-9. [pmid: 15113776].
40 Ross JS, et al. Use of recommended ambulatory care services: is the Veterans Affairs quality gap narrowing?. Arch Intern Med. 2008;168(9):950-8. [pmid: 18474759].
41 Selim AJ, et al. Risk-adjusted mortality as an indicator of outcomes: comparison of the Medicare Advantage Program with the Veterans’ Health Administration. Med Care. 2006;44(4):359-65. [pmid: 16565637].
42 Selim AJ, et al. Change in health status and mortality as indicators of outcomes: comparison between the Medicare Advantage Program and the Veterans Health Administration. Qual Life Res. 2007;16(7):1179-91. [pmid: 17530447].
43 Weeks WB, et al. Comparing the characteristics, utilization, efficiency, and outcomes of VA and non-VA inpatient care provided to VA enrollees: a case study in New York. Med Care. 2008;46(8):863-71. [pmid: 18665066].
44 Weeks WB, et al. Comparing measures of patient safety for inpatient care provided to veterans within and outside the VA system in New York. Qual Saf Health Care. 2008;17(1):58-64. [pmid: 18245221].
45 Harada ND, Villa VM, Andersen R. Satisfaction with VA and non-VA outpatient care among veterans. Am J Med Qual. 2002;17(4):155-64. [pmid: 12153068].
46 Selim AJ, et al. Differences in risk-adjusted mortality between medicaid-eligible patients enrolled in medicare advantage plans and those enrolled in the veterans health administration. J Ambul Care Manage. 2009;32(3):232-40. [pmid: 19542813].
47 Petersen LA, et al. Comparison of use of medications after acute myocardial infarction in the Veterans Health Administration and Medicare. Circulation. 2001;104(24):2898-904. [pmid: 11739303].
48 Ritchie JL, et al. A comparison of percutaneous transluminal coronary angioplasty in the Department of Veterans Affairs and in the private sector in the State of Washington. Am J Cardiol. 1998;81(9):1094-9. [pmid: 9605048].
49 Wright SM, et al. Increasing use of Medicare services by veterans with acute myocardial infarction. Med Care. 1999;37(6):529-37. [pmid: 10386565].
50 Nelson KM, et al. The association between health insurance coverage and diabetes care; data from the 2000 Behavioral Risk Factor Surveillance System. Health Serv Res. 2005;40(2):361-72. [pmid: 15762896].
51 Piette JD. Satisfaction with care among patients with diabetes in two public health care systems. Med Care. 1999;37(6):538-46. [pmid: 10386566].
52 Weeks WB, et al. Veterans Health Administration and Medicare outpatient health care utilization by older rural and urban New England veterans. J Rural Health. 2005;21(2):167-71. [pmid: 15859054].
53 Gordon HS, et al. Using severity-adjusted mortality to compare performance in a Veterans Affairs hospital and in private-sector hospitals. Am J Med Qual. 2000;15(5):207-11. [pmid: 11022367].
54 Berlowitz DR, et al. Purchasing or providing nursing home care: can quality of care data provide guidance. J Am Geriatr Soc. 2005;53(4):603-8. [pmid: 15817005].
55 Leslie DL, Rosenheck RA. Comparing quality of mental health care for public-sector and privately insured populations. Psychiatr Serv. 2000;51(5):650-5. [pmid: 10783185].
56 Leslie DL, Rosenheck RA. Benchmarking the quality of schizophrenia pharmacotherapy: a comparison of the Department of Veterans Affairs and the private sector. J Ment Health Policy Econ. 2003;6(3):113-21. [pmid: 14646004].
57 Rosenheck RA, et al. Benchmarking treatment of schizophrenia: a comparison of service delivery by the national government and by state and local providers. J Nerv Ment Dis. 2000;188(4):209-16. [pmid: 10789997].
58 Stineman MG, et al. Inpatient rehabilitation after stroke: a comparison of lengths of stay and outcomes in the Veterans Affairs and non-Veterans Affairs health care system. Med Care. 2001;39(2):123-37. [pmid: 11176550].
59 Cox RM, Alexander GC, Gray GA. Hearing aid patients in private practice and public health (Veterans Affairs) clinics: are they different?. Ear Hear. 2005;26(6):513-28. [pmid: 16377990].
60 Rosenthal GE, et al. Mortality and length of stay in a veterans affairs hospital and private sector hospitals serving a common market. J Gen Intern Med. 2003;18(8):601-8. [pmid: 12911641].
61 Kaboli PJ, et al. Length of stay as a source of bias in comparing performance in VA and private sector facilities: lessons learned from a regional evaluation of intensive care outcomes. Med Care. 2001;39(9):1014-24. [pmid: 11502958].
62 Khuri SF, et al. The Department of Veterans Affairs’ NSQIP: the first national, validated, outcome-based, risk-adjusted, and peer-controlled program for the measurement and enhancement of the quality of surgical care. National VA Surgical Quality Improvement Program. Ann Surg. 1998;228(4):491-5. [pmid: 9790339].