# METHODS

## TOPIC DEVELOPMENT

This project was nominated by William Duncan, Associate Deputy Undersecretary of Health for Quality and Safety.

The final key question was:

Compare and contrast studies that assess VA and non-VA quality of care for surgical, non-surgical and other medical conditions.

## SEARCH STRATEGY

We were first given a list of articles by VA Central Office that represented examples of articles addressing possible VA and non-VA comparisons. Once these were reviewed, we then completed a Medline search for similar types of articles. Between the initial list and the subsequent search, we retrieved 222 articles. These were then screened by two physicians trained in the critical analysis of literature. Articles that both agreed were to be included were then reviewed, and all data were narratively summarized. When differences in the initial assessment (inclusion vs not) occurred, the specific articles were then discussed with at least one other senior member of the review team. Because of the focus on US health care, we searched Medline only. The search strategy is listed in Appendix 6.

## STUDY SELECTION

Articles were reviewed utilizing a two page screening form (see Appendix 3). Each article was reviewed by two physicians, one with a surgical background and the other specializing in internal medicine. To be included in our report, the article had to present a comparison of quality of clinical data in VA and United States (US) non-VA settings, and had to have been published no earlier than 1990. The screening form also collected basic information about the articles: whether or not the data for the comparison was sufficiently contemporaneous (within 1 to 2 years of each other); how VA and non-VA data were assembled; from what geographical area(s) VA and non-VA data were collected and analyzed; what conditions were covered in the quality assessment; what features of quality were measured (structure, process, and/or outcomes); and how similar were the specifications for the quality assessments comparing VA and non-VA samples.

## DATA ABSTRACTION

Data were independently abstracted using a one-page abstraction form (see Appendix 4). Data for surgically related articles were abstracted by our surgical reviewer, and for non-surgical articles the internal medicine reviewer completed the abstraction process. Once the forms were completed, all data were reviewed by the review team. The following data were abstracted from included trials: sample size for both VA and non-VA sources, years of data collection covered for both VA and non-VA sources; control variables; primary outcomes; and secondary or associated findings.

## QUALITY ASSESSMENT

Each article was given an overall assessment, which was based on the following criteria: time frames; samples (both VA and non-VA); quality measurements; outcomes; importance of measures; and statistical methods. Each of these factors was assigned a grade (A, B, or C) based on the data abstraction grading guidelines developed (see Appendix 5). The overall assessment was predicated on the global assessment of the article, considering the individual components, but was not an average. Thus an article that had, for example, a critical flaw in methodology would be a “C,” even if other issues were satisfactory. During this phase, or during the initial assessment or data abstraction phases, disagreements or questions about the articles or information were discussed with at least one senior member of the team in order to reach concurrence.

## DATA SYNTHESIS

We first classified articles as dealing with surgical or medical therapy. Within these categories, we further grouped articles according to their clinical content area, for example, one group contained medical studies about the quality of cardiovascular disease care. Within these categories, studies were still sufficiently heterogenous to preclude meta-analysis. Consequently, our synthesis is narrative.

## PEER REVIEW

A draft version of this report was sent to six peer reviewers, of which one responded. Her comments and our responses are presented in Appendix 7. Peer Review Comments Table.