# INTRODUCTION

## BACKGROUND

As noted by Ashton et al, VA healthcare system transformation began in 1995, moving from a hospital-based system to a more comprehensive healthcare model with the goal of providing the best health care in America2. There have been numerous reports comparing VA health care quality with non-VA care, both scholarly and in the lay media1, 3–5. However, there has not been a systematic evaluation of the published evidence comparing care across systems. Therefore, VA Central Office asked the Evidence Synthesis Program located at the VA Greater Los Angeles Healthcare System, West Los Angeles campus to perform such a review.