# PEER REVIEW COMMENTS TABLE

Location | Comment | Change
Executive Summary, Background | I am curious about why you do not mention the “Best Care Anywhere” book and others, and only focus upon negative? | Background updated to incorporate suggested citation.
Executive Summary, Conclusion | Might clarify that medication process of care showed VA was better, but procedural process of care not uniformly better (ie angiography). | “…and interventional procedures” added for clarification.
Hospital and Nursing Home Care, Summary | “Racial mortality differences” to “mortality rates for racial minorities” | Change incorporated
Mental Health, Summary | It wasn’t clear in the summary how outpatient follow-up rates could be worse when outpatient continuity was better, so I tried to clarify: “…and [timely] outpatient visit follow-up rates [after discharge] were worse in the VA, but continuity of care [in the outpatient setting]…” | Change incorporated
Conclusions, paragraph 9 | Same comments as in the mental health section above: “…equivalent racial mortality differences…” to “equivalent mortality rates across racial groups” | Change incorporated