# SEARCH STRATEGY

TOPIC: Veterans Hospitals and Non-Veterans Hospitals Quality of Care – Search Methodology

NOTE: Search strategy was derived from subject terms used in 34 articles provided by the project

Database: PubMed

Years Covered: 1996–2009 (August)

Number of results: 432

Search Strategy:

hospitals, veterans[MeSH Terms] OR hospitals, veterans[majr] OR hospitals, veterans/standards OR hospitals, veterans/statistics and numerical data OR united states department of veterans affairs OR united states department of veterans affairs/standards OR united states department of veterans affairs/statistics and numerical data OR united states department of veterans affairs/utilization