# DATA ABSTRACTION GRADING GUIDELINES

Assessment (grade levels detailed below):

1. Time frames
  A. Contemporaneous time frames
  B. All between A and C
  C. non-contemporaneous
2. Samples (both VA and non-VA)
  A. representative or national samples (both VA and non-VA)
  B. All between A and C
  C. small, limited, unequal or non-representative samples
3. Quality measurements
  A. specified and identical measures with a similar assessment format for those measures
  B. All between A and C
  C. dissimilar measures and/or dissimilar assessment methods
4. Outcomes
  A. outcomes are either well established clinical endpoints or processes strongly associated with well-established clinical endpoints
  B. All between A and C
  C. outcomes are structures, processes or clinical endpoints that are not well-established or are indirect measures of quality
5. Importance of measures (e.g. number of clinically relevant indicators, potential impact of indicators)
  A. High
  B. Medium
  C. Low
6. Statistical methods
  A. Sufficient sample size and/or methods appropriate to address hypothesis(ses)
  B. All between A and C
  C. Insufficient sample size and/or methods questionable to address hypothesis(ses)

Overall assessment/assignment of level: Measured as an average of grades assigned above