# DATA ABSTRACTION FORM

Data Abstraction Form: Round Two