# SCREENER FORM

Screener Form