# EVIDENCE TABLE OF MEDICAL AND NON-SURGICAL STUDIES

| | VA Sample | | | Non-VA Sample
Author; Year | Category | Data Level | Sample Size | Years Collected | Data Level | Sample Size | Years Collected | Conditions | Outcomes | Primary Findings | Final Grade
Asch, S.M., et al.; 2004^23^ | General, mult conditions | Mult. VISNs | 596 | 1997–1999 | Nat’l | 992 | 1996–2000 | CHF, DM, IHD, HTN, Pulmonary Disease, Preventive Care, Cancer, Osteo-arthritis, Depression, TIA/Stroke | adherence to 348 indicators targeting 26 conditions | VA scored better on adjusted overall quality 67% vs 51%; chronic disease care (72 vs 59) and preventive care (64 vs 44), but not acute care. | A
Bansal, D., et al.; 2005^24^ | Cardiovascular | Single ctr | 92/117 | 2002 | Nat’l | not described | 2002 | IHD | use of aspirin, betablockers, aceinhibitors, heparin, gp2a3b inhibitors among pts with MI | Use of all these agents were higher in the Little Rock VA compared to the rest of Arkansas and the entire US | B
Barnett, M.J., et al.; 2006^25^ | Other | Nat’l | 123633 | 2002–2003 | Nat’l | 157517 | 2000–2001 | Other safety | use of potentially inappropriate medications among the elderly | Compared with private sector patients, VA patients were less likely to receive any inappropriate medication (21% vs. 29%, P <0.001), and in each classification: always avoid (2% vs. 5%, P <0.001), rarely appropriate (8% vs. 13%, P<0.001), and some indications (15% vs. 17%, P <0.001). | B
Berlowitz, D.R., et al.; 2005^54^ | Hospital and nursing home care | One VISN | 3802/961 | 1997–1999 | Lrg geo area | 52986/142452 | 1997–1999 | Other medical/nonsurgical condition | Risk-adjusted rates of pressure ulcer development, functional decline, behavioral decline, and mortality. | Veterans in VA nursing homes were significantly (Po.05) less likely to develop a pressure ulcer (odds ratio (OR)50.63) but more likely to experience functional decline (OR 51.6) than veterans in community nursing homes. Veterans in VA nursing homes were also less likely to die but more likely to experience behavioral decline, but these differences did not achieve statistical significance after risk adjustment. | A
Busch, S.H., et al.; 2004^26^ | Mental health care | Nat’l | 27713 | 2000–2001 | Nat’l | 4852 | 2000–2001 | Depression | Receipt of 84, 140, and 181 of antidepressant therapy among patients with initial diagnosis of depression | The VA slightly outperformed the private sector in the prescription of antidepressants during the acute phase of treatment, the first 84 days (84.7 compared with 81 percent) and during the maintenance phase of treatment, the first 181 days (53.9 compared with 50.9 percent). The findings persisted after adjustment for age and sex but lost significance after adjustment for comorbid conditions. | A
Campling, B.G., et al.; 2005^27^ | Other | One VISN | 862 | 1995–1999 | Lrg geo | 27936 | 1995–1999 | Cancer | survival following diagnosis of lung cancer | The median survival was 6.3 months for VA patients compared with 7.9 months for patients in the rest of the state, and the 5-year overall survival rate was 12% for VA patients compared with 15% for patients in the rest of the state. The Cox model showed a hazard ratio for VA patients compared with non-VA patients of 1.22 (P_ 0.001) after adjusting for age, disease stage, and race. | B
Chi, R.C., et al.; 2006^28^ | General, prevention | Nat’l | 3265 | 2003 | Nat’l | 10677/40331 | 2003 | Preventive Care | Influenza and pneumococcal vaccination | Among veterans, Influenza and vccinatin rates highers for VA users compared to non-users. For veterans, VA care was independently associated with influenza vaccination (adjusted OR 1.8; 95%CI 1-5-2.2) and pneumococcal vaccionation (adjusted OR 2.4; 95%CI 2.0–2.9). | A
Cox, R.M., et al.; 2005^59^ | Other | Mult VISNs | 151 | 2000–2003 | Mult ctrs | 79 | 2000–2003 | Other medical/nonsurgical condition | satisfaction with hearing aid fitting | Three weeks after the fitting, VA patients reported more satisfaction with their hearing aids. On some measures VA patients reported more benefit, but different measures of benefit did not give completely consistent results. | B
Gordon, H.S., et al.; 2000^53^ | Hospital and nursing home care | Single ctr | 5016 | 1993 | Nat’l | 850000 | 1991 | Other medical/nonsurgical condition | hospital mortality | Adjusted death rates were similar in the VA and a private sector sample | B
Harada, N.D., et al.; 2002^45^ | General, patient satisfaction | One VISN | 1262/840 dual | 2000 | Lrg geo areao | 550 | 2000 | Other medical/nonsurgical condition | patient satisfaction with outpatient care | VA users were 2–8 times more satisfied than va non-users on 5 of 10 measures of satisfaction. VA users were less satified than non-VA users on one measure – number of days waited for an appointment. | B
Jha, A.K., et al.; 2003^29^ | General, mult conditions | Nat’l | 48505–84503 | 1994–2000 | Nat’l | diff. to ascertain | 1997–2001 | CHF, DM, IHD, Preventive care | 3 preventive measures, 3 diabetes measures, 5 ami measures, 2 chf measures | The VA outperformed the Medicare fee-for-service program on all 11 similar indicators from 1997 to 1999 and of 12 of 13 indicators in 2000. | A
Jha, A.K., et al.; 2007^30^ | General, prevention | Nat’l | 48505–84503 | 1994–2000 | Nat’l | diff. to ascertain | 1997–2001 | Preventive Care | 3 preventive measures, 3 diabetes measures, 5 ami measures, 2 chf measures | The VA outperformed the Medicare fee-for-service program on all 11 similar indicators from 1997 to 1999 and of 12 of 13 indicators in 2000. | A
Kaboli, P.J., et al.; 2001^61^ | Hospital and nursing home care | Single ctr | 1142 | 1994–1995 | Mult ctrs | 51249 | 1994–1995 | Other medical/nonsurgical condition | risk adjusted mortality | Using logistic regression to adjust for severity, the odds of death was similar in VA patients, relative to private sector patients (OR 1.16, 95% CI 0.93–1.44; P = 0.18). Using proportional hazards regression and censoring patients at hospital discharge, the risk for death was lower in VA patients (hazard ratio 0.70; 95% CI 0.59–0.82; P <0.001). | B
Kerr, E.A., et al.; 2004^31^ | Diabetes | Mult. VISNs | 1285 | 2000–2001 | Mult. Ctrs | 6616 | 2001–2002 | DM | Process of care measures of quality as derived from the Diabetes Quality Improvement, Project accountability and measurement set, Intermediate outcomes, Patient satisfaction with care | After adjustment, VA significantly outperformed mgd care on all process of care measures. Intermediate outcome of blood pressure control was comparable between the two cohorts, however the VA cohort had significantly greater percentage of patients tight HgbA1C and LDL control. Patients reported similar overall satisfaction in the two cohorts, though there was significantly greater satisfaction with diabetes care in the VA. | A
Keyhani, S., et al.; 2007^32^ | General, prevention | Nat’l | 171/1009/145 | 2000–2003 | Nat’l | 3552/576 | 2000–2003 | Preventive Care | self-reported use of influenza vaccination, pneumonia vaccianation, serum cholesterol screening | Veterans receiving care through VA reported 10% greater use of influenza vaccination (P<.05), 14% greater use of pneumococcal vaccination (P<.01), And a nonsignificant 6% greater use of serum cholesterol screening (P=.1), than did veterans receiving care through Medicare HMOs. Veterans receiving care through Medicare FFS reported less use of all 4 preventive measures (P<.01) than did veterans receiving care through Medicare HMOs. | B
Krein, S.L., et al.; 2007^33^ | Hospital and nursing home care | Nat’l | 95 hospitals | 2005 | Nat’l | 421 hospitals | 2005 | Other medical/nonsurgical condition | regular use of specific prevention modalities (maximum sterile barrier precautions, use of chlorhexadine gluconate for insertion site and antimicrobial CV catheters, routine change of catheters, use of antimicrobial impreganated dressing); also a composite measure of max sterile barrier, chlorhexadine and avoidance of routine changes. | Adjusted findings revealed that VA hospitals were significantly more likely to use chlorhexadine gluconate (OR 4.8, 95%CI 1.6–15.0) and/or to use a composite approach (OR 2.1, 95%CI 1.0–4.2) as compared with non-VA hospitals. | B
Landrum, M.B., et al.; 2004^34^ | Cardiovascular | Nat’l | 15259/13129 | 1996–1999 | Nat’l | 447445/384470 | 1996–1999 | IHD | mortality (30 day and one year) | VA pts had significantly higher one year mortality rates across all years studied; 30 day mortality rates were higher in VA in 1997 however 30 day mortality rates decreased overtime and were comparable between the two sites by 1999. | B
Leslie, D.L., et al.; 2000^55^ | Mental health | Nat’l | 181132 | 1993–1997 | Nat’l | 12163 | 1993–1995 | Depression, Psychosis/schizophrenia, other medical/nonsurgical condition | Readmission rates and outpatient follow-up care following hospitalization for a psychiatric or substance abuse disorder | This study found that, overall, private-sector mental health inpatients had shorter lengths of stay, more days to the next inpatient readmission, and lower readmission rates within 14, 30, or 180 days of discharge compared with VA mental health inpatients. Although VA patients had higher continuity-of-care scores, moderately higher proportions of private-sector patients had an outpatient visit within 30 and 180 days after discharge. Private-sector patients also had fewer days to the first outpatient visit and more outpatient visits in the six months after discharge. | B
Leslie, D.L., et al.; 2003^56^ | Mental health | Nat’l | 2636 | 2000 | Nat’l | 1318 | 2000 | Psychosis/schizophrenia | adherence to treatment guidelines for antipsychotic prescribing | Patients in the VA and private sector were equally likely to receive an antipsychotic regimen that complied with PORT guidelines. | B
Nelson, K.M., et al.; 2005^50^ | Diabetes | Nat’l | 254/281 | 2000 | Nat’l | 10632 | 2000 | DM | They studied five self-reported measures of diabetes self-management and preventive care practices | Persons who received care through the VA were more likely to report taking a diabetes education class and HbA1c testing than those covered by private insurance. | B
Petersen, L.A., et al.; 2000^35^ | Cardiovascular | Nat’l | 2486/13310 | 1994–1995 | Nat’l | 29249/41754 | 1994–1995 | IHD | comparison of coexisting conditions, severity of AMI and mortality at 30 days & one year | Adjusted rates of mortality at 30 days and one year were not significantly different among VA and Medicare patients after AMI (OR 0.94, 95% CI 0.82–1.07 and OR 0.94, 95% CI 0.84–1.05 respectively). | B
Petersen, L.A., et al.; 2001^47^ | Cardiovascular | Nat’l | 2486 | 1994–1995 | Nat’l | 29249 | 1994–1995 | IHD | use of thrombolytics, _-blockers, ACE inhibitors, or aspirin among ideal candidates following an acute myocardial infarction | Ideal VA candidates were more likely to undergo thrombolytic therapy at arrival (OR [VA relative to Medicare] 1.40 [1.05, 1.74]) or to receive ACE inhibitors (OR 1.67 [1.12, 2.45]) or aspirin (OR 2.32 [1.81, 3.01]) at discharge and equally likely to receive _-blockers (OR 1.09 [1.03, 1.40]) at discharge. | A
Petersen, L.A., et al.; 2003^36^ | Cardiovascular | Nat’l | 1665/2486 | 1994–1995 | Nat’l | 19305/29249 | 1994–1995 | IHD | use of angiography (appropriate use) and mortality | After accounting for patient characteristics and need for angiography, VA pts were significantly less likely to receive angiography (43.9 vs 51%, OR 0.75, 95% CI 0.57–0.96). After accounting for hospital and capability of cardiac interventions, underuse of angiography and mortality did not differ significantly between patient groups. | A
Piette, J.D.; 1999^51^ | Diabetes | Mult ctrs | 310 | 1996–1997 | Mults ctrs | 228 | 1996–1997 | DM | Six dimensions of patient satisfaction | VA patients were more satisfied than were county patients overall and with 5 of 6 dimensions of their care. | B
Polsky, D., et al.; 2007^37^ | Hospital and nursing home care | Nat’l | 369155/427367 | 1995–2001 | Lrg geo | 1509891/3861953 | 1995–2001 | CHF, IHD, Pulmonary Disease, TIA/Stroke | 30 day mortality (for white and black males after hospital admission for any of the above conditions) | After risk adjustment, racial (black vs white) differences in 30 day mortality rates after admission for 6 medical conditions were similar among VA and non-VA care settings. | B
Rehman, S.U., et al.; 2005^38^ | Cardiovascular | One VISN | 12366 | 2001–2003 | Lrg geo | 7734 | 2001–2003 | HTN | control of blood pressure below 140/90 | Blood pressure control to below 140/90 mmHg was comparable among white hypertensive men at VA (55.6%) and non-VA (54.2%) settings (P=.12). In contrast, BP control was higher among African American hypertensive men at VA (49.4%) compared with non-VA (44.0%) settings (P_.01), even after controlling for age, numerous comorbid conditions, and ruralurban classification. Being in a non-VA site was negatively associated with blood control adjusted OR 0.839 (0.742–0.949) | A
Reiber, G.E., et al.; 2004^39^ | Diabetes | Nat’l | 535 | 2000 | Nat’l | 1848/9055 | 2000 | DM, Preventive care | a1c testings foot exam, diabetes education, bp measurement, cholesterol measurement, sigmoidoscop, fotb testing among patients with diabetes | Veterans who use VA have higher rates of foot exams, diabetes education, and sigmoidoscopy an da lower rate of a1c testing compared to veterans who did not use the VA. There were non-signifcatn difference for eye exams, bp measurements, cholestestorol testing and fobt screening. | A
Ritchie, J.L., et al.; 1998^48^ | Cardiovascular | One VISN | 8326 | 1993–1994 | Lrg geo area | 6666 | 1993–1994 | IHD | 10 and 30 day mortality, 10 and 30 day use of cardiac bypass surgery | Overall mortality and same-admission bypass surgery rates were similar for patients undergoing PTCA in the VA and Washington State hospitals. | B
Rosenheck, R.A., et al.; 2000^57^ | Mental health | Mult ctrs | 192/274 | 1994–1996 | Mult ctrs | 96/184 | 1994–1996 | Psychosis/schizophrenia | adherence to port recommendations | On 5 of 26 Schizophrenic Patient Outcomes Research Team treatment recommendations, a smaller proportion of VA than non-VA patients adhered to standards. Four of these reflected reduced access among VA patients to psychosocial services such as work therapy, job training, or case management services. | B
Rosenthal, G.E., et al.; 2003^60^ | Hospital and nursing home care | Single ctr | 1960 | 1994–1995 | Mult ctrs | 157147 | 1994–1995 | Other medical/nonsurgical condition | mortality | Risk adjusted inhospital mortality was similar for VA and private sector patients OR 1.07 95%CI 0.74–1.54. | B
Ross, J.S., et al.; 2008^40^ | General, mult conditions | Nat’l | 10007 | 2000–2004 | Nat’l | 393873 | 2000–2004 | DM, IHD, HTN, Preventive Care | self reported use of 17 recommended health care services including cancer prevention, cardiovascular risk reduction, diabetes management and infection prevention. | VAMC care was associated with greater use of recommended services in both years of study (6/17 services more used in 2000, 12/17 more used in 2004) | B
Selim, A.J., et al.; 2006^41^ | General, mortality and health status | Nat’l | 420514/1.5m | 1999–2004 | Nat’l | 584294/879202 | 1998–2004 | Other medical/nonsurgical condition | Risk adjusted mortality | After adjusting for case-mix, the HR for mortality in the MAP was significantly higher than that in the VA (HR, 1.404; 95% CI _ 1.383–1.426). | B
Selim, A.J., et al.; 2007^42^ | General, mortality and health status | Nat’l | 12177/16725 | 1998–2000 | Nat’l | 26225/62614 | 1998–2000 | None | Risk-adjusted 2 year mortality, change in physical and mental health status | Higher risk-adjusted mortality in the VA compared to Medicare Advantage (2 year mortality 7.6% in VA vs. 9.2% in MA); There were no significant differences in the probability of being alive with the same or better PCS except for the South (VA 65.8% vs. MAP 62.5%, P = .0014). VA patients had a slightly higher probability than MAP patients of being alive with the same or better MCS (71.8% vs. 70.1%, P = .002) | B
Selim, A.J., et al.; 2009^46^ | General, mortality and health status | Nat’l | 2361 | 1999–2000 | Nat’l | 1912 | 1999–2000 | Other medical/nonsurgical condition | 3 year risk adjusted mortality rate | The adjusted HR of mortality in the MA dual enrollees was significantly higher than in the VHA dual enrollees (HR, 1.260 [95% CI, 1.044–1.520]). | B
Stineman, M.G., et al.; 2001^58^ | Other | Nat’l | 3056 | 1994–1995 | Nat’l | 52382 | 1995 | TIA/Stroke | functional independence | Stroke patients receiving rehabilitation in the VA setting were discharged with slightly better functional outcomes. | B
Weeks, W.B., et al.; 2008^43^ | Hospital and nursing home care | One VISN | 105026 | 1998–2000 | Lrg geo | 163853 | 1998–2000 | None | length of stay, readmission within 30 days | Across conditions, the length of stay was longer for VA patients compared with non-VA patients. In logistic regression, VA care was not a significant predictor of 30 day readmission for veterans <65 years old, however for veterans >=65 years of age initial VA admission was associated with a significantly higher odds of readmission within 30 days than non-VA index admission (OR 2.79, 95%CI 1.4–5.6) | B
Weeks, W.B., et al.; 2008^44^ | Hospital and nursing home care | One VISN | 50429 | 1998–2000 | Lrg geo | 74017 | 1998–2000 | Patient Safety Indicators | Risk adjusted rates of non-obsteric patient safety indicators | Rates similar for 9 of 15 PSIs, ulcer, sepsis, iatrogenic infection, postop resp failure, post op metabolic derangement lower in VA, mortality higher in VA for low-risk DRGs | B
Wright, S.M., et al.; 1999^49^ | Cardiovascular | Nat’l | 14853 | 1992–1995 | Nat’l | 32745 | 1992–1995 | IHD | 30 day and 1 year adjusted mortality rates | After adjusting for patient characteristics, the odds of 30-day mortality were not significantly different between patients admitted to VA basic service hospitals (reference) and patients admitted to any other type of hospital within either system of care. The odds of 1-year mortality were significantly lower in patients admitted to Medicare cardiac surgery hospitals (OR 0.88, 95% CI 0.79–0.98) compared to patients admitted to VA basic service hospitals | B