# EVIDENCE TABLE OF SURGICAL STUDIES

| | VA Sample | | | Non-VA Sample
Author; Year | Category | Data Level | Sample Size | Years Collected | Data Level | Sample Size | Years Collected | Conditions | Outcomes | Primary Findings | Final Grade
Austin, G.L., et al.; 2004^6^ | Solid Organ Transplantation | Single ctr | 149 | 1991–2000 | Single med ctr | 285 | 1991–2000 | Other Surgical | mortality at 1,3,5 years | VA patients had increased mortality rates as assessed by Kaplan-Meier curves. However after adjusting for gender, donor age, recipient age, etiology of liver disease and MELD score, hospital status was not a significant predictor of mortality RR 1.15 (95% CI 0.94–1.43) | A
Bilimoria, K.Y., et al.; 2007^7^ | Oncology | Nat’l | 513 | 1985–2004 | Nat’l | 12,756/18,299 | 1985–2004 | General surgical, Surgical Oncology | 60 day and 3 year mortality | Unadjusted and adjusted mortality rates at 60 days and 3 years were comparable between VA, academic and community hospital settings for resection of stage I and II pancreatic cancer. | B
Feria, M.I., et al.; 2003^8^ | Cardiac | Nat’l | 808 | 1995–1998 | Mult ctrs | 18,299 | 1996–1998 | IHD, Cardiothoracic | perceptions of various dimensions of care | VA patients were more likely than non-VA patients to note a problem with patient care; when analysis limited to teaching hospital settings, VA patients remained more likely to note a problem with care in 5 dimensions. | B
Fink, A.S., et al.; 2007^9^ | General | Nat’l | 5157 | 2001–2004 | Mult. Ctrs | 27467 | 2001–2004 | General surgical | 30 day postoperative morbidity and mortality | Risk adjusted mortality rates are comparable between PS and VA patients, although setting of care did not enter the mortality regression model. Risk adjusted morbidity was higher in the PS compared with the VA OR 0.8 (CI 0.71–0.90) | B
Gill, J.S., et al.; 2007^10^ | Solid Organ Transplantation | Nat’l | 7395 | 1995–2004 | Nat’l | 144651/357345 | 1995–2004 | Other surgical | time to treatment | Both VA-insured and Medicare/Medicaid-insured patients were approximately 35% less likely to receive transplants than patients with private insurance (hazard ratio [HR] 0.65; 95% CI 0.60 to 0.70; P _ 0.0001). Most of this difference was explained by the fact that VA patients were less likely to be placed on the wait-list (HR 0.71; 95% CI 0.67 to 0.76), but even listed VA patients received transplants less frequently than those insured privately (HR 0.89; 95% CI 0.82 to 0.96). | A
Glasgow, R.E., et al.; 2007^11^ | Oncology | Nat’l | 377 | 2001–2004 | Mult. Ctrs | 692 | 2001–2004 | Other surgical | postoperative outcomes (primarily morbidity and mortality) | Adjusting for case mix differences, postoperative morbidity and mortality rates for pancreatectomy were higher in the VA compared with the PS (OR 1.581, 95% CI 1.084–2.307 and 2.533 95% CI 1.020–6.290 respectively). | A/B
Hall, B.L., et al.; 2007^12^ | Endocrine | Nat’l | 2814 | 2001–2004 | Mult. Ctrs | 357345 | 2001–2004 | General surgical, head and neck | 30 day morbidity and mortality; specific adverse event rates, LOS | Overall 30 day morbidity and mortality do not differ significantly in the VA vs PS in risk adjusted model. Mortality event rate is too low to accurately evaluate, odds ratio for morbidity associated with VA care is 1.25 ( 95% CI 0.87–1.78) | B
Henderson, W.G., et al.; 2007^13^ | General | Nat’l | 9409818 | 2001–2004 | Mult. Ctrs | 18399 | 2001–2004 | General surgical | 30 day postoperative morbidity and mortality | After risk adjustment for patient comorbidities and severity of illness, the odds of mortality at 30 days were higher in the VA compared with the PS (OR 1.23, 95% CI ). There was no significant difference in morbidity at 30 days among the sites. | A/B
Hutter, M.M., et al.; 2007^14^ | Vascular | Nat’l | 5174 | 2001–2004 | Mult. Ctrs | 30058 | 2001–2004 | Vascular | 30 day postoperative morbidity and mortality | Risk adjusted mortality was comparable among the two groups, although hospital site/type did not enter the stepwise regression model. Accounting for comorbidities and severity of illness, postoperative morbidity rates were lower in the VA population, OR 0.84 (95% CI 0.78–0.92) | A/B
Johnson, R.G., et al.; 2007^15^ | Vascular | Nat’l | 458 | 2001–2004 | Mult. Ctrs | 3535 | 2001–2004 | Vascular | 30 day postoperative morbidity and mortality | After risk adjustment, no significant difference in 30 day mortality rates among VA and PS female vascular patients. After adjusting for severity of illness, 30 day complication/morbidity rates were significantly lower in the VA compared with the PS (OR 0.60, 95% CI 0.44–0.81) | B
Lancaster, R.T., et al.; 2007^16^ | General | Nat’l | 237 | 2001–2004 | Mult. Ctrs | 783 | 2001–2004 | General surgical | post-operative morbidity and mortality at 30 days; also evaluated LOS, need for re-operation and occurrence of 18 specific postoperative events | Risk adjusted outcomes suggest that 30 day post-operative morbidity and mortality rates in the VA compared with the PS for hepatic resections do not vary significantly. (after risk adjustment, morbidity rates and mortality were comparable in VA and PS. Comparing Morbidity of VA w/PS OR was 0.94 (95% CI 0.62–1.42) and Mortality OR was 1.623 (95% CI 0.61–4.32)) | A/B
Lautz, D.B., et al.; 2007^17^ | General | Nat’l | 374 | 2001–2004 | Mult. Ctrs | 2064 | 2001–2004 | Other surgical | 30 day postoperative outcomes: morbidity (overall, specific adverse events, # complications), mortality, LOS | No significant difference in postop morbidity or mortality among women in the VA versus non-VA settings (16.07 vs 12.02 % p =0.21 and 0.89 vs 0.42%, p=0.47). Unadjusted and adjusted morbidity rates were higher among men treated at the VA versus non-VA (OR 2.77, 95% CI 1.78–4.31 unadjusted and OR 2.29, 95% CI 1.28–4.10 adjusted). Unadjusted mortality rates significantly higher among men treated at VA versus non-VA((1.91% vs 0.25% p=0.03). | A/B
Moore, D., et al.; 2003^18^ | Solid Organ Transplantation | Single ctr | 380 | 1990–2002 | Single med ctr | 1429 | 1990–2002 | Other surgical | graft survival; patient survival, Karnofsky score, SF36 | No significant difference in graft or patient survival in liver, heart, or kidney between veteran and nonveteran patients, and survival statistics were consistent with recently published national data | A
Neumayer, L., et al.; 2007^19^ | Oncology | Nat’l | 644 | 2001–2004 | Mult. Ctrs | 3179 | 2001–2004 | General surgical | 30 day postoperative morbidity and mortality, LOS | After adjusting for comorbidities and preoperative factors, there was no significant difference in 30 day morbidity or mortality in female patients at the VA compared with the PS (OR 1.404, 95% CI 0.894–2.204). | B
Rosenthal, G.E., et al.; 2003^20^ | Cardiac | Nat’l | 19266 | 1993–1996 | Lrg geo area | 44247/9696 | 1993–1996 | Cardiothoracic | in hospital mortality | Adjusting for patient-level predictors and volume, the odds of death was higher in VA patients, relative to private sector patients (OR, 1.34; 95% CI, 1.11–1.63; P <0.001). | A
Turrentine F.E., et al.; 2007^21^ | Endocrine | Nat’l | 178 | 2001–2004 | Mult. Ctrs | 371 | 2001–2004 | Other surgical | 30 day morbidity and mortality | Unadjusted morbidity and mortality rates were higher in VA compared with PS (16.3% vs 6.7%, p=0.003 and 2.8% vs. 0.4%, p=0.0074). Mortality event rate was too low for adjustment. Adjusting for comorbidities, the 30 day postoperative morbidity ratio in the VA versus the PS was no longer significant (adjusted OR 1.33, 95%CI 0.49–3.6 compared with unadjusted OR 2.75, 95% CI: 1.55–4.91). | B
Weiss, J.S., et al.; 2006^22^ | Vascular | One VISN | 140 | 1997–2002 | Lrg geo | 6949 | 1997–2002 | Vascular | perioperative mortality, stroke and cardiac complications | After risk adjustment, having surgery at the VA was not a significant predictor of death (OR 2.98, 95% CI 0.51–17.6), stroke (OR .95, 95% CI 0.3–3.4 ) or cardiac complications(OR 1.07 95% CI 0.37–3.1) | B