# Appendices

APPENDIX 1 EVIDENCE TABLE OF SURGICAL STUDIES

APPENDIX 2 EVIDENCE TABLE OF MEDICAL AND NON-SURGICAL STUDIES

APPENDIX 3 SCREENER FORM

APPENDIX 4 DATA ABSTRACTION FORM

APPENDIX 5 DATA ABSTRACTION GRADING GUIDELINES

APPENDIX 6 SEARCH STRATEGY

APPENDIX 7 PEER REVIEW COMMENTS TABLE