# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1 What tools are used to screen for PTSD in primary care settings, and what are their characteristics (i.e., length, format/administration, response scale)?

Screening tools that focus on evaluating traumatic experiences are not likely to be clinically useful given the high population prevalence of traumatic events and the much lower conditional probability of developing PTSD.3,15,38 Consequently, all screening tools reviewed in this report were those that evaluated PTSD symptoms. There is a limited number of studies examining screening tools for PTSD symptoms in primary care that examined their utility using “gold standard” structured diagnostic interviews. Most of these studies had significant methodologic limitations which limits the strength of the evidence and our confidence in these findings. Common limitations included non-random screening, selective recruitment for diagnostic interviews, and diagnostic interviews conducted with knowledge of screen results. Half of the studies used Veteran or military samples, and in these samples the following tools were evaluated: PCL (and its abbreviated versions), PC-PTSD, Breslau scale, SPAN, and SIP.

There were twelve screening tools that were used to detect PTSD, and validated using a gold standard structured diagnostic interview, in a primary care setting. Three of the screening tools were truncated versions of longer screens also included in the review. Five of the screening tools were used to screen for multiple disorders. All screens were self-administered paper and pencil screening tests, and ranged from one to twenty-seven items. Response options for screen items ranged from dichotomous scoring (yes/no) to 5 point graded frequency or severity scales.

### Key Question #2 What are the psychometric properties and utility of the screening tools (sensitivity, specificity, likelihood ratios, predictive values, area under curve, reliability)?

Of the screens for which area under the curve (AUC) statistics were reported, AUCs ranged from 0.75 to 0.93. No AUC statistics were available for the PDI-4A, ADD or M-3. Performance of the moderate length screens (PC-PTSD, Breslau scale, SPAN) were comparable, though there was very weak evidence that the SPAN performed less well than the PC-PTSD or the Breslau scales. However, there were no high quality studies examining the performance of the PC-PTSD in a primary care setting.

The optimal cut-score for the most commonly used screen, the PTSD Checklist (PCL), varied across clinical settings according to differences in PTSD prevalence rates and sample compositions. Because the 17 item screen has a more graded scoring distribution, optimal cut-scores could be more precisely determined for a given clinical setting. In contrast, across studies, the intermediate length screens all had sharp drop-offs just under the recommended cut-scores. This suggests that the optimal cut score of an intermediate length screen is less likely to vary across populations and settings, and can therefore be more easily adopted by different healthcare systems. However, it also means that there is a steeper trade-off between sensitivity and specificity in cut-scores that differ only by one point, which may have significant policy and resource implications.

Screens not specific to PTSD but for which there was a study that evaluated the ability of the screen to detect PTSD performed less well than those that focused on the detection of PTSD exclusively. In some clinical settings, this might be preferable, as “false positives” on non-PTSD specific screens may reflect psychiatric symptomatology requiring further evaluation.

### Key Question #3 What information is there about the implementability (e.g., ease of administration, patient satisfaction) of PTSD screening tools in primary care clinics?

Only two studies evaluated logistical or experiential aspects of using a screening tool in clinical practice. One of these evaluated the time patients took to fill out the longest screen and determined that the time investment was only between 5-10 minutes and could be completed prior to the start of the medical appointment. Only one study evaluated the impact of screen use on the process of care and found that it facilitated discussion of mental health issues with primary care providers. There was no evidence regarding readability, speed of administration, ease of interpretability, or patient satisfaction for the remainder of the instruments and no comparative studies of these implementation issues.

Only three studies reported the time it took for patients to fill out the screening instruments, and only one systematically explored patients' and providers' experiences of screening tool implementation.12 In the study that evaluated implementation of screening, both patients and providers reported that pre-appointment mental health screening facilitated discussion of mental health issues in the subsequent primary care encounter. Most providers (80%) reported that the screen was helpful in their interactions with their patients. The authors reported that this 27 item screen of multiple psychiatric conditions common seen in primary care patients took patients only 5 minutes to complete, and that only 1% of patients felt that they had insufficient time to complete it prior to their appointment.

### Key Question #4 Do the psychometric properties and utility of each of the screening tools differ according to age, gender, race/ethnicity, substance abuse, or other comorbidities?

There was very limited information regarding the modifying effect of patient demographic characteristics or clinical comorbidities on screen performance.

Of the studies that were available, there was weak evidence that the clinical utility of the PC-PTSD may be better for men vs. women, and no information as to whether its performance characteristics vary as a function of patient age, race, or ethnicity. Similarly, there is weak evidence that the performance of the SPAN does not vary by patient gender, age, or race. The PCL appears to function comparably for men as it does for women, but there is weak evidence that Veterans who are younger than 50 and African American may not be identified as having PTSD as accurately by the PCL than Veterans who are white and/or older. There was no evidence of screen performance characteristics among other minority groups. More information is needed as to whether screens, particularly the PC-PTSD, work equally well regardless of patient age, gender, race, or ethnicity so as to ensure that VA's screening program does not contribute to treatment disparities.

There was no information regarding the impact of specific psychiatric comorbidities on the performance characteristics of any of the screening tools in the primary care setting.

## LIMITATIONS

There are a limited number of studies examining screening tools for PTSD in primary care that examined their utility using “gold standard” structured diagnostic interviews. Most studies had significant methodologic limitations which limits our confidence in these findings. Confidence in these findings is also somewhat limited because of variation in what studies used as a “gold standard.” Although all “gold standard” interviews were based on the same diagnostic criteria, the specific interviews used, the scoring rules for the interviews, and the skill of the interviewers differed across studies. This variation may have subtly altered the performance characteristics of the screens across studies.

The appropriate balance of sensitivity and specificity of a screening tool depends on the purpose of the tool and the health care policy underlying its use. Consequently, the effectiveness of a particular screening tool depends on the precision with which the cut score is optimized given the population prevalence of the target condition and the intent of the screening program. This contextually-specific balance could not be assessed in the current review.

## CLINICAL CONSIDERATIONS

Use of PTSD screening tools can improve detection of PTSD among primary care patients. While widely implemented, no randomized controlled trials evaluating the benefits and harms of screening and subsequent treatment of PTSD have been conducted. Such studies, particularly among individuals seen in primary care clinics, are needed.

The primary potential harm to the patient of screening for PTSD is the potential for misdiagnosis which could lead to labeling and potential harms of treatment. The principal harm to the health care system is that limited mental health resources become used to evaluate patients with potential PTSD diagnoses, some of whom are subsequently found not to have PTSD, leaving fewer resources available to provide treatment. On the other hand, there is also potential harm in not screening for PTSD and thereby missing cases that may benefit from detection and treatment. Not only is there a missed opportunity to treat an often debilitating illness that causes significant suffering, but there may also be a risk of allowing untreated illness to contribute to secondary medical and mental health problems. Determining the most useful instrument and the optimal cut score for that instrument would help to balance these potential harms.

Six studies used Veteran samples exclusively. Two enrolled only female Veterans. Four evaluated some version of the PCL, two evaluated the PC-PTSD, and the SIPS, Breslau scale, and SPAN were each evaluated in single studies. The evidence suggests that the PCL, PC-PTSD, Breslau scale and SPAN all perform at least as well in Veteran as in non-Veteran samples. Given the limited number of studies evaluating each screening tool and the lack of studies comparing the performance of a screen in samples with and without Veterans, there was insufficient evidence to determine whether screens were better at detecting possible PTSD among Veterans vs. non-Veterans.

Currently, the VA uses the PC-PTSD, which is short, easy to administer and has good psychometric properties. As with many shorter screens, the PC-PTSD has a steeper gradient of endorsement between cut-scores than the PCL, which may result in either an over- or under-sensitive screening tool depending on the cut-score selected and the population in which it is used. For longer screens, such as the PCL, cut-scores can be more carefully “calibrated” to the target population. However, the PCL also contains many items that may be endorsed by Veterans who have mental health concerns other than PTSD. Because of this, the specificity of the PCL is comparable to that of the more general GAD-7 when cut-scores lower than the mid-forties are used; however, use of a higher score lowers the screen's sensitivity. Whether use of the PCL rather than the PC-PTSD would improve screening accuracy is unknown.

An alternative would be a two-staged screening approach such as that used by two of the studies in the review. For example, in the study by Meltzer-Brody (2004), patients were first screened for traumatic experiences prior to receiving the SPAN.54 However, the performance of the SPAN was not appreciably better than in other studies without the traumatic experiences inquiry. A two-stage screening approach was also used by Gaynes (2010).12 In that study, symptom scales of the M-3 were only scored if patients endorsed either functional impairment or suicidality items. Perhaps this is the reason that the likelihood ratios for the M-3 tended to be better than those for other very short screens.

Within the coming year, the new Diagnostic Statistical Manual for mental disorders will be released (www.dsm5.org/Pages/Default.aspx). The proposed diagnostic criteria for PTSD overlap considerably with those in the currently used DSM-IV, but differ sufficiently that the performance of PTSD screening tools such as those covered in this review will need to be evaluated relative to the new criteria.

## RECOMMENDATIONS FOR FUTURE RESEARCH

1. The new DSM-5 diagnostic criteria for PTSD are soon to be released. Although it is unlikely that the overall performance of the screening tool used by VA (PC-PTSD) and other tools reviewed in this report will be appreciably altered given the new diagnostic criteria, the importance of PTSD detection and treatment in VA requires a high degree of confidence in tools used in clinical care of Veterans with PTSD. Accordingly, the PC-PTSD should be validated against the DSM-5 PTSD criteria.
2. VA has worked to minimize healthcare disparities. Because there is weak and inconsistent evidence of possible variation in screen performance related to patient characteristics, more information is needed to determine whether screening tools for PTSD work equally well regardless of patient age, gender, race, ethnicity.
3. Although psychiatric comorbidity is common among Veterans with PTSD, there is no information about whether the performance of mental health screening tools, such as the PC-PTSD, are altered in the presence of specific psychiatric comorbidities (e.g., traumatic brain injury).
4. There are no studies examining the impact of mental health screening on the primary care encounter within the VA system, and only one implementation study was done in a community setting. It would be helpful to have more information about how PTSD screens can be best be integrated into clinical practice.
5. The success of a screening program depends on whether identification of the target condition in the population improves the outcome of those who have the condition.3,5 As noted in the IOM report,3 this is assumed to be true for PTSD but has never been proven. It would be helpful to know if implementation of screening for PTSD has had a positive impact on the mental and physical health of the VA population, as well as the financial and opportunity costs to the VA health care system of PTSD screening implementation. To adequately address this important clinical and research gap, a randomized controlled trial or methodologically sound comparative effectiveness trial of PTSD screening of Veterans in primary care settings is needed.