# REFERENCES

1 Graves RE, Freedy JR, Aigbogun NU, Lawson WB, Mellman TA, Alim TN. PTSD treatment of African American adults in primary care: the gap between current practice and evidence-based treatment guidelines. J Natl Med Assoc. 2011;103(7):585-93. [pmid: 21999033].
2 Magruder KM, Frueh BC, Knapp RG, et al. Prevalence of posttraumatic stress disorder in Veterans Affairs primary care clinics. Gen Hosp Psychiatry. 2005;27(3):169-79. [pmid: 15882763].
3 Institute of Medicine. Treatment for posttraumatic stress disorder in military and veteran populations: Initial assessment. Washington, DC. The National Academies Press. 2012.
4 Rona RJ, Hyams KC, Wessely S. Screening for psychological illness in military personnel. JAMA. 2005;293(10):1257-60. [pmid: 15755948].
5 Gilbody S, Sheldon T, Wessely S. Should we screen for depression?. BMJ. 2006;332(7548):1027-30. [pmid: 16644833].
6 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
7 Simel DL. Update: primer on precision and accuracy. Simel DL, Rennie D, editors. Rational Clinical Examination: The Evidence-Based Clinical Diagnosis. New York, NY. McGraw-Hill. 2008:9-16.
8 Yeager DE, Magruder KM, Knapp RG, Nicholas JS, Frueh BC. Performance characteristics of the posttraumatic stress disorder checklist and SPAN in Veterans Affairs primary care settings. Gen Hosp Psychiatry. 2007;29(4):294-301. [pmid: 17591505].
9 Prins A, Ouimette PC, Kimerling RE, et al. The primary care PTSD Screen (PC-PTSD): development and operating characteristics. [see Corrigendum 2004;9(4):151]. Prim Care Psychiatry. 2003;9(1):9-14.
10 Gore KL, Engel CC, Freed MC, Liu X, Armstrong DW 3rd. Test of a single-item posttraumatic stress disorder screener in a military primary care setting. Gen Hosp Psychiatry. 2008;30(5):391-7. [pmid: 18774421].
11 Freedy JR, Steenkamp MM, Magruder KM, et al. Post-traumatic stress disorder screening test performance in civilian primary care. Fam Pract. 2010;27(6):615-24. [pmid: 20622049].
12 Gaynes BN, DeVeaugh-Geiss J, Weir S, et al. Feasibility and diagnostic validity of the M-3 checklist: a brief, self-rated screen for depressive, bipolar, anxiety, and post-traumatic stress disorders in primary care. Ann Fam Med. 2010;8(2):160-9. [pmid: 20212303].
13 Kimerling R, Ouimette P, Prins A, et al. Brief report: Utility of a short screening scale for DSM-IV PTSD in primary care. J Gen Intern Med. Jan. 2006;21(1):65-67. [pmid: 16423126].
14 Kroenke K, Spitzer RL, Williams JBW, Monahan PO, Lowe B. Anxiety disorders in primary care: prevalence, impairment, comorbidity, and detection. Ann Intern Med. 2007;146(5):317-25. [pmid: 17339617].
15 Breslau N, Peterson EL, Schultz LR. A second look at prior trauma and the posttraumatic stress disorder effects of subsequent trauma: a prospective epidemiological study. Arch Gen Psychiatry. 2008;65(4):431-7. [pmid: 18391131].
16 Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):617-27. [pmid: 15939839].
17 Roberts AL, Gilman SE, Breslau J, Breslau N, Koenen KC. Race/ethnic differences in exposure to traumatic events, development of post-traumatic stress disorder, and treatment-seeking for post-traumatic stress disorder in the United States. Psychol Med. 2011;41(1):71-83. [pmid: 20346193].
18 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC. 1994.
19 Ramchand R, Schell TL, Karney BR, Osilla KC, Burns RM, Caldarone LB. Disparate prevalence estimates of PTSD among service members who served in Iraq and Afghanistan: possible explanations. J Trauma Stress. 2010;23(1):59-68. [pmid: 20135699].
20 Rosenheck R, Stolar M, Fontana A. Outcomes monitoring and the testing of new psychiatric treatments: work therapy in the treatment of chronic post-traumatic stress disorder. Health Serv Res. 2000;35(1 Pt 1):133-51. [pmid: 10778827].
21 Andersen J, Wade M, Possemato K, Ouimette P. Association between posttraumatic stress disorder and primary care provider-diagnosed disease among Iraq and Afghanistan veterans. Psychosom Med. 2010;72(5):498-504. [pmid: 20368471].
22 Breslau N. The epidemiology of trauma, PTSD, and other posttrauma disorders. Trauma Violence Abuse. 2009;10(3):198-210. [pmid: 19406860].
23 Marshall RD, Olfson M, Hellman F, Blanco C, Guardino M, Struening EL. Comorbidity, impairment, and suicidality in subthreshold PTSD. Am J Psychiatry. 2001;158(9):1467-73. [pmid: 11532733].
24 Smith MW, Schnurr PP, Rosenheck RA. Employment outcomes and PTSD symptom severity. Ment Health Serv Res. 2005;7(2):89-101. [pmid: 15974155].
25 Durai UN, Chopra MP, Coakley E, et al. Exposure to trauma and posttraumatic stress disorder symptoms in older veterans attending primary care: comorbid conditions and self-rated health status. J Am Geriatr Soc. 2011;59(6):1087-92. [pmid: 21649614].
26 Kartha A, Brower V, Saitz R, Samet JH, Keane TM, Liebschutz J. The impact of trauma exposure and post-traumatic stress disorder on healthcare utilization among primary care patients. Med Care. 2008;46(4):388-93. [pmid: 18362818].
27 Uddin M, Aiello AE, Wildman DE, et al. Epigenetic and immune function profiles associated with posttraumatic stress disorder. Proc Natl Acad Sci U S A. 2010;107(20):9470-5. [pmid: 20439746].
28 Schnurr PP, Green BL. Trauma and Health: Physical Health Consequences of Exposure to Extreme Stress. Washington, DC. American Psychological Association. 2004.
29 Ahmadi N, Hajsadeghi F, Mirshkarlo HB, Budoff M, Yehuda R, Ebrahimi R. Post-traumatic stress disorder, coronary atherosclerosis, and mortality. Am J Cardiol. 2011;108(1):29-33. [pmid: 21530936].
30 Gros DF, Frueh BC, Magruder KM. Prevalence and features of panic disorder and comparison to posttraumatic stress disorder in VA primary care. Gen Hosp Psychiatry. 2011;33(5):482-8. [pmid: 21816481].
31 Yaffe K, Vittinghoff E, Lindquist K, et al. Posttraumatic stress disorder and risk of dementia among US veterans. Arch Gen Psychiatry. 2010;67(6):608-13. [pmid: 20530010].
32 Pietrzak RH, Goldstein RB, Southwick SM, Grant BF. Physical health conditions associated with posttraumatic stress disorder in U.S. older adults: results from wave 2 of the National Epidemiologic Survey on Alcohol and Related Conditions. J Am Geriatr Soc. 2012;60(2):296-303. [pmid: 22283516].
33 Calhoun PS, McDonald SD, Guerra VS, et al. Clinical utility of the Primary Care-PTSD Screen among U.S. veterans who served since September 11, 2001. Psychiatry Res. 30. 2010;178(2):330-5. [pmid: 20483463].
34 Cohen BE, Gima K, Bertenthal D, Kim S, Marmar CR, Seal KH. Mental health diagnoses and utilization of VA non-mental health medical services among returning Iraq and Afghanistan veterans. J Gen Intern Med. 2010;25(1):18-24. [pmid: 19787409].
35 Zen AL, Whooley MA, Zhao S, Cohen BE. Post-traumatic stress disorder is associated with poor health behaviors: findings from the heart and soul study. Health Psychol. 2012;31(2):194-201. [pmid: 22023435].
36 Management of Post-Traumatic Stress Working Group. VA/DoD clinical practice guideline for management of post-traumatic stress, version 2.0. Department of Veterans Affairs and Department of Defense. 2010. Available at: www.healthquality.va.gov/ptsd/cpg_PTSD-FULL-201011612.pdf. January 18, 2013.
37 Spoont MR, Murdoch M, Hodges J, Nugent S. Treatment receipt by veterans after a PTSD diagnosis in PTSD, mental health, or general medical clinics. Psychiatr Serv. 2010;61(1):58-63. [pmid: 20044419].
38 Wang PS, Berglund P, Olfson M, Pincus HA, Wells KB, Kessler RC. Failure and delay in initial treatment contact after first onset of mental disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):603-13. [pmid: 15939838].
39 Blake DD, Weathers FW, Nagy LM, et al. The development of a Clinician-Administered PTSD Scale. J Trauma Stress. 1995;8(1):75-90. [pmid: 7712061].
40 First MB, Spitzer RL, Gibbon M, Williams JBW. Structured Clinical Interview for DSM-IV Axis Disorders. Washington, DC. American Psychiatric Association. 1997.
41 Sheehan DV, Lecrubier Y, Sheehan KH, et al. The Mini-International Neuropsychiatric Interview (M.I.N.I.): the development and validation of a structured diagnostic psychiatric interview for DSM-IV and ICD-10. J Clin Psychiatry. Suppl 20. 1998;59:22-33. [pmid: 9881538].
42 Foa E, Riggs D, Dancu C, Rothbaum B. Reliability and validity of a brief instrument for assessing post-traumatic stress disorder. J Trauma Stress. 1993;6:459-74.
43 Breslau N, Peterson EL, Kessler RC, Schultz LR. Short screening scale for DSM-IV posttraumatic stress disorder. Am J Psychiatry. 1999;156(6):908-11. [pmid: 10360131].
44 Meltzer-Brody S, Churchill E, Davidson JR. Derivation of the SPAN, a brief diagnostic screening test for post-traumatic stress disorder. Psychiatry Res. 1999;88(1):63-70. [pmid: 10641587].
45 Davidson JR, Book SW, Colket JT, et al. Assessment of a new self-rating scale for post-traumatic stress disorder. Psychol Med. 1997;27(1):153-60. [pmid: 9122295].
46 Weathers F, Litz B, Herman D, Huska J, Keane T. The PTSD Checklist (PCL): Reliability, validity, and diagnostic utility. San Antonio , TX. Annual Convention of the International Society for Traumatic Stress Studies. 1993.
47 Andrykowski MA, Cordova MJ, Studts JL, Miller TW. Posttraumatic stress disorder after treatment for breast cancer: prevalence of diagnosis and use of the PTSD Checklist-Civilian Version (PCL-C) as a screening instrument. J Consult Clin Psychol. 1998;66(3):586-90. [pmid: 9642900].
48 Bliese PD, Wright KM, Adler AB, Cabrera O, Castro CA, Hoge CW. Validating the primary care posttraumatic stress disorder screen and the posttraumatic stress disorder checklist with soldiers returning from combat. J Consult Clin Psychol. 2008;76(2):272-81. [pmid: 18377123].
49 Lang AJ, Stein MB. An abbreviated PTSD checklist for use as a screening instrument in primary care. Behav Res Ther. 2005;43(5):585-94. [pmid: 15865914].
50 Houston JP, Kroenke K, Davidson JR, et al. PDI-4A: an augmented provisional screening instrument assessing 5 additional common anxiety-related diagnoses in adult primary care patients. Postgrad Med. 2011;123(5):89-95. [pmid: 21904090].
51 Means-Christensen AJ, Sherbourne CD, Roy-Byrne PP, Craske MG, Stein MB. Using five questions to screen for five common mental disorders in primary care: diagnostic accuracy of the Anxiety and Depression Detector. Gen Hosp Psychiatry. 2006;28(2):108-18. [pmid: 16516060].
52 Spitzer RL, Kroenke K, Williams JB, Lowe B. A brief measure for assessing generalized anxiety disorder: the GAD-7. Arch Int Med. 2006;166(10):1092-7. [pmid: 16717171].
53 Dobie DJ, Kivlahan DR, Maynard C, et al. Screening for post-traumatic stress disorder in female Veteran's Affairs patients: validation of the PTSD checklist. Gen Hosp Psychiatry. 2002;24(6):367-74. [pmid: 12490337].
54 Lang AJ, Laffaye C, Satz LE, Dresselhaus TR, Stein MB. Sensitivity and specificity of the PTSD checklist in detecting PTSD in female veterans in primary care. J Trauma Stress. 2003;16(3):257-64. [pmid: 12816338].
55 Meltzer-Brody S, Hartmann K, Miller WC, Scott J, Garrett J, Davidson J. A brief screening instrument to detect posttraumatic stress disorder in outpatient gynecology. Obstet Gynecol. 2004;104(4):770-6. [pmid: 15458900].
56 Walker EA, Newman E, Dobie DJ, Ciechanowski P, Katon W. Validation of the PTSD checklist in an HMO sample of women. Gen Hosp Psychiatry. 2002;24(6):375-80. [pmid: 12490338].