# METHODS

## TOPIC DEVELOPMENT

This project was nominated by David Simel, MD, and endorsed by the Office of Mental Health Services. The key questions and scope were refined with input from a technical expert panel.

The final key questions were:

- Key Question #1. What tools are used to screen for PTSD in primary care settings, and what are their characteristics (i.e., length, format/administration, response scale)?
- Key Question #2. What are the psychometric properties and utility of the screening tools (sensitivity, specificity, likelihood ratios, predictive values, area under curve, reliability)?
- Key Question #3. What information is there about the implementability (e.g., ease of administration, patient satisfaction) of PTSD screening tools in primary care clinics?
- Key Question #4. Do the psychometric properties and utility of each of the screening tools differ according to age, gender, race/ethnicity, substance abuse, or other comorbidities?

## SEARCH STRATEGY

We searched Ovid MEDLINE from 1981 to October 2012 using standard search terms (Appendix A). The search was limited to peer-reviewed articles involving adult human subjects and published in the English language. A similar search strategy was used for searching the National Center for PTSD's Published International Literature On Traumatic Stress (PILOTS) database (http://www.ptsd.va.gov/professional/pilots-database/pilots-assessment.asp) (Appendix A). Additional citations were identified from reference lists of relevant articles and existing reviews.

## STUDY SELECTION

Titles and abstracts were reviewed by researchers trained in the critical analysis of literature. We retrieved the full-text of potentially relevant articles for further review. We sought to include studies done in settings and with populations most relevant to the United States Veteran population. Therefore, we excluded the following: studies that did not involve screening of adults in primary care settings in the United States, studies that did not report an evaluation of a screening tool for PTSD symptoms, studies that did not include a gold-standard structured diagnostic clinical assessment of PTSD as a comparator, studies that did not report outcomes of interest (diagnostic accuracy or information related to implementation of a screening tool), and studies that had a screening sample size of fewer than 50 participants. Information about gold standard structured diagnostic interviews used as validation tools by included studies is presented in Table 1. There are other structured interviews that met our gold standard inclusion criteria (e.g., Diagnostic Interview Schedule or DIS) but were not utilized in studies meeting other eligibility criteria for this review and so are not included in the table.

Table 1 Gold Standard Structured Diagnostic Interviews for Diagnosing PTSD

Gold Standard | Description | Scoring^*^ | Administration Time
Clinician Administered PTSD Scale (CAPS) | Structured diagnostic interview of PTSD symptoms based on DSM-IV criteria. Assesses each of the 17 DSM-IV symptoms of PTSD as well as the impact of symptoms on occupational and social functioning, validity of responses, and five symptoms associated with PTSD (guilt, gaps in awareness, derealization, and depersonalization).39 | Items scored for frequency (0 - 4) and in intensity (0 - 4). Symptom typically considered present if frequency ≥ 1 and intensity ≥ 2. | 45-60 minutes
Structured Clinical Interview for DSM–IV (SCID) | Semi-structured interview that assesses major DSM-IV diagnoses. Interview is broken down into individual modules representing categories of diagnoses that can be administered individually.40 | Each symptom is scored as present, absent, or subthreshold. The minimum number of symptoms required to meet diagnostic criteria must be coded as present. | Varies depending on modules administered and the number of disorders present. Generally, 1-2 hours.
Mini-International Neuropsychiatric Interview (MINI) | Brief structured diagnostic interview that assesses major psychiatric disorders within both DSM-IV (Axis I) and ICD-10. Items were developed by psychiatrists both within the United States and across Europe.41 | Each symptom with the diagnosis coded as ‘yes’ or ‘no’. | 15 minutes
PTSD Symptom Scale – Interview (PSS-I) | Semi-structured interview for the 17 symptoms used to diagnose PTSD according to the DSM-IV. Assesses presence and severity symptoms related to a single identified traumatic event in the past 2 weeks, which differs from the 1 month time frame within the DSM-IV.42 Has also been validated for symptoms in the last month. | Seventeen items each scored from 0 (not at all) to 3 (5 or more time per week/very much). Symptom considered present if it receives a score of 1 or higher. | 20 minutes
Composite International Diagnostic Interview (CIDI) | Structured diagnostic interview that assesses both DSM-IV (Axis I) and ICD-10 conditions. Disorders are grouped in modules so modules of interest can be administered individually. | Yes/No response items and items with variable response options. Diagnosis based on DSM-IV or ICD-10 criteria. | Approximately 2 hours for entire diagnostic interview.

DSM = Diagnostic Statistical Manual

* If a study reported a different method of scoring a gold standard assessment, the method is reported in the text of the report.

## DATA ABSTRACTION

Study characteristics, screening instrument(s) used, diagnostic measures, method of administration, base rate of PTSD, screening sample and interview sample response rates, and results (sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, area under curve) were extracted from each identified study by co-investigators under the supervision of the Principal Investigator, a VA psychologist and core investigator. We noted whether the study involved specific sample populations (e.g., Veterans, women, age over 60 years, etc.) and rated the study on the quality components of interest. The data extraction form is presented in Appendix B. A list of psychometric terms and how they are determined is included in Table 2.

Table 2 Diagnostic Accuracy Terms Used in this Report

Metric | Definition | Calculation | Relation to other Metrics
Prevalence | Frequency of a disorder within a target population. | Number of true positives/total sample | Impacts the predictive values (positive, negative) of screening; if prevalence is low, PPV decreases and NPV increases.
Cut Score | Test score used to divide the target population or test sample into true positive and negative cases. | Ideal cut score typically based on desired sensitivity/specificity trade-off | Increasing the cut score typically increases specificity and decreases sensitivity.
Sensitivity | Probability that the screen will be positive when the person has the disease (true positive fraction). | True positives/(true positives + false negatives) | Sensitivity increases with higher cut scores. Higher sensitivity results in higher LR+ and lower LR−.
Specificity | Probability that the screen will be negative when the person does not have the disease (true negative fraction). | True negatives/(true negatives + false positives) | Specificity decreases with higher cut scores. Higher specificity results in lower LR− and higher LR+.
Positive Predictive Value (PPV) | Proportion of positive screens that are true positives. | True positives/(true positives + false positives) | PPV increases with higher base rates: (Sensitivity)(base rate)/[(Sensitivity)(base rate) + (1 − specificity)(1 − base rate)].
Negative Predictive Value (NPV) | Proportion of negative screens that are true negatives. | True negatives/(true negatives + false negatives) | NPV decreases with higher base rates: (Specificity)(1 − base rate)/[(specificity)(1 − base rate) + (1 − sensitivity) (base rate)].
Likelihood Ratio – Positive (LR+) | Ratio between the probability of a positive screen given the disease is present and the probability of a positive screen given the disease is not present. | True positives/false positives Or Sensitivity/(1 – specificity) | Likelihood ratio – positive: increases with increased sensitivity or increased specificity.
Likelihood Ratio – Negative (LR-) | Ratio between the probability of a negative screen given the disease is present and the probability of a negative screen given the disease is not present. | False negatives/true negatives Or (1 – sensitivity)/specificity | Likelihood ratio – negative: decreases with increased specificity or increased sensitivity.
Area Under the Curve (AUC) | Area under a ROC^*^ curve. Measures discrimination of patients that do or do not have the disease using all possible cut scores. AUC=1.0 indicates perfect discrimination. AUC=0.5 indicates test is no better than a coin toss. | Parametric and nonparametric methods available depending on assumptions | Shows trade-off between sensitivity and specificity, not necessarily how test performs at cut score to be used in practice.

* ROC = Receiver operating characteristic; ROC curve is plot of false positives on x-axis vs. true positives on y-axis.

## QUALITY ASSESSMENT

We assessed the quality of studies pertaining to key questions #2 and #3 using selected criteria from the QUality Assessment of Studies of Diagnostic Accuracy included in Systematic reviews (QUADAS) tool.6 As noted on the data extraction form (Appendix B), we focused on: 1) the representativeness of the screening and interview samples, 2) the time lag between screening and diagnostic assessments, 3) the number and selection method of screened participants who were interviewed, and 4) whether the diagnostic interviews were conducted blind to the screening results.

## RATING THE BODY OF EVIDENCE

In addition to quality ratings of individual study features, we summarized the overall quality of the evidence for each study using methods developed for the Journal of the American Medical Association Rational Clinical Examination series.7 One of five levels of evidence was assigned to each study based on sample size, independence and representativeness of the study samples, quality of the gold standard assessment procedure, and whether diagnostic assessments were completed blind to screening status. Definitions for each of the five levels of evidence ratings are presented in Appendix C, and our application of them to each study in Appendix F. Studies that met the lowest level of evidence (i.e., Level V) were excluded from the review. The body of evidence for each screening tool was evaluated qualitatively taking into account the strength of the current evidence base.

## DATA SYNTHESIS

We constructed a study characteristics table showing sample characteristics (screening and interview samples) and methodological quality. We constructed an evidence table with gold standard diagnostic assessment tools, base rate of PTSD, and outcomes (sensitivity, specificity, positive and negative predictive values, area under receiver operating characteristic (ROC) curve, and positive and negative likelihood ratios) organized by screening instrument. We compiled a summary of findings for each question based on qualitative and semi-quantitative synthesis of the results. We identified and highlighted findings from studies involving Veterans and military personnel.

## PEER REVIEW

A draft version of this report was reviewed by technical experts as well as clinical leadership. Their comments and our responses are presented in Appendix D.