# SPECIFIC ASSOCIATION OF RCE LEVEL OF EVIDENCE RATINGS TO QUADAS ITEM RATINGS AS APPLIED IN THIS REVIEW

RCE Level of Evidence Rating | QUADAS Item 1 Sample size of screening sample | QUADAS Item 2 Representativeness of screening sample viz. target population/ selection method | QUADAS Item 3 Sample size/representativeness of Interview sample viz. screening sample | QUADAS Item 4 Quality of gold standard and its administration | QUADAS Item 5 Blinded/concurrent diagnostic evaluations
I | Large | Representative of target population/randomly selected or consecutive sample | All of screening sample or randomly selected representative sample | In person by trained diagnostician | Yes
II | Small | Representative of target population/randomly selected or consecutive sample | All of screening sample or randomly selected representative sample | In person by trained diagnostician | Yes
III * | Small [underlined: or] Large | Representative sample [underlined: or] convenience/non-representative sample | Random selection [underlined: or] non-representative interview sample | In person or by telephone by trained diagnostician | Yes
IV † | Small | Convenience/non-representative sample | Non-random interview sample | Telephone by trained research assistants | No
V | Not included in Systematic Review

QUADAS = QUality Assessment of Studies of Diagnostic Accuracy included in Systematic reviews tool (Whiting 2003)6

RCE = Rational Clinical Examination (Simel 2008)7 (see Appendix C)

* Level III studies have either a small sample size and lower ratings on QUADAS 2 or QUADAS 3, or a larger sample size and lower ratings on both QUADAS 2 and QUADAS 3

† Level IV studies may have a higher rating on one of the QUADAS 1-4 criteria but have lower ratings in the other 3 criteria