# SEARCH STRATEGIES

## I Ovid MEDLINE

Search Strategy:

1. exp mass screening/ or screen*.mp.
2. exp Stress Disorders, Post-Traumatic/
3. (posttraumatic stress or posttraumatic stress disorder* or post-traumatic stress disorder* or ptsd).mp.
4. combat disorder*.mp. or exp Combat Disorders/)
5. or/2-4
6. 1 and 5
7. limit 6 to (english language and humans and yr=”1981 -Current”)

## II PILOTS Database

Search textword “screen*”

With Limits:

English language

1980 -2012

And Descriptor categories:

“self report instruments, adults” or “self report instruments”, “ptsd assessment instruments”, “dissociation assessment instruments”, “acute stress disorder assessment instruments”, “assessment instruments” or ”assessment”