# RESULTS

Our general approach throughout the Results section is first to describe the relevant systematic reviews and then to describe the primary literature, with syntheses of the reviews and the primary literature occurring in conjunction with descriptions of the primary literature. This approach to integrating existing systematic reviews and new primary literature into a new “complex systematic review” was adopted and implemented in accordance with the recommendations for conducting complex systematic reviews proposed by Whitlock and colleagues.36

## LITERATURE SEARCH AND STUDY CHARACTERISTICS

### Systematic Reviews

Using the combined literature search of PubMed, Embase, PsycINFO, and Cochrane databases (Appendix A), we identified references for 560 potential systematic reviews (Figure 2). Of these, 528 were excluded at the title-and-abstract level, and 30 were excluded after conducting a full-text review. Two eligible reviews were retained: Cuijpers and colleagues45 and Cape and colleagues.46

Figure 2 LITERATURE FLOW DIAGRAM

Cuijpers45 completed a good-quality meta-analysis of 15 studies that examined psychotherapeutic interventions for depression in primary care. Studies were identified through an Internet-accessible database of psychotherapy trials47 that was created by the authors via comprehensive literature searches in PubMed, PsycINFO, Embase, and the Cochrane Central Register of Controlled Trials from 1966 to December 2007. Included studies had interventions ranging in length from 6 to 16 sessions; only CBT and PST used 8 or fewer sessions. The majority of treatments were either CBT or PST, with two studies examining IPT and one study examining psychodynamic counseling. Most comparator conditions were care as usual (which was noted as being poorly described and variable in the reviewed studies), three were placebo, and two were waitlist. Half of the studies contained participants diagnosed with MDD, and the other half contained participants with other depressive conditions. Eight studies were conducted in the U.K., five in the U.S., and two in the Netherlands. The risk of bias varied across studies. Of the 15 trials, 13 assessed outcomes blind to treatment assignment, 10 were analyzed using the intent to treat principle, and dropout rates varied from 3.3 to 41.2%. The authors separated the seven studies with six or fewer sessions from the eight studies with more than six sessions; this subgroup analysis was of particular interest for the present review.

Cape46 completed a good-quality meta-analysis and meta-regression of 34 studies examining the effectiveness of brief psychological therapies in primary care for anxiety disorders, depressive disorders, and mixed anxiety and depression. Studies were identified via searches in MEDLINE, Embase, and PsycINFO databases from inception through July 2008. Included RCTs had number of sessions ranging from 2.3 to 9.8, with a median and mode of six sessions. Active treatment conditions had roughly equal distributions between studies for CBT, PST, and counseling. All comparator conditions were “general practitioner care as usual,” which was not further described. Seven studies included patients with anxiety disorders, 14 included patients with depression, and 13 included patients with mixed anxiety and depression. Of the 14 depression studies, 6 enrolled patients with MDD, 6 enrolled mixed depressive disorders including minor depression, and 2 enrolled only those with minor depression. For the 14 depression studies, 8 were analyzed using the intent-to-treat principle, and 10 had lost to followup less than 20%. The number with blinded outcome assessment was not reported. Approximately two-thirds of the studies were conducted in the U.K., with the remaining third conducted in other European countries and the U.S. The authors separately reviewed the studies of brief psychotherapy for depression, and this subgroup analysis was used in the present review.

After articles from the Cuijpers45 and Cape46 reviews were screened by two independent reviewers, nine articles representing eight unique studies met eligibility criteria and were retained for further analysis in tandem with the additional original research studies identified from the primary literature searches.

### Primary Literature

The combined searches for primary literature in electronic databases (MEDLINE, Embase, and PsycINFO), in a well-documented Internet-accessible database of psychotherapy trials,47 and in bibliographies of included studies (Appendix A) identified 866 citations. Of these, 12 articles representing 7 unique studies met eligibility criteria (Figure 2).

Study characteristics from the 15 relevant RCTs of brief psychotherapy—8 from the Cuijpers45 and Cape46 reviews and 7 from the additional RCTs identified in our primary literature search— are summarized in Table 3. Characteristics of psychotherapy interventions used in the 15 RCTs of brief psychotherapy are summarized in Table 4.

Table 3 Summary of Study Characteristics

| Author, year | Depressive disorder | Age mean (SD) | % Female | % White | Setting | Recruitment | Most distal followup^a^ | Depression outcomes | Quality^b^
RCTs from systematic reviews | Barrett et al., 2001^48^ and Frank et al., 2002^4^ | Minor depression or dysthymia | 43.6 (NR) | 67% | 89% | PC | Screening and referral | 11 weeks | HRSD-17; HSCL-20 | –
RCTs from systematic reviews | Dowrick et al., 2000^5^ | MDD, dysthymia, adjustment disorder, or other depression | NR; Range: 18-65 | 66% | NR | PC | Screening from census and registry | 52 weeks | BDI | –
RCTs from systematic reviews | Lynch et al., 1997^49^ | Elevated depressive symptoms without MDD | 48.4 (NR) | 86% | NR | PC | Screening | 7 weeks | HRSD; BDI | –
RCTs from systematic reviews | Lynch et al., 2004^50^ | Elevated depressive symptoms | 38.5 (13.7) | 83% | NR | PC | Screening | 6 weeks | HRSD; BDI; DHP | –
RCTs from systematic reviews | Mynors-Wallis et al., 1995^51^ | MDD | 37.1 (11.4) | 77% | 95% | PC | Referral | 12 weeks | HRSD; BDI | –
RCTs from systematic reviews | Scott et al., 1997^52^ | MDD | 41 (10.4) | 67% | NR | PC | Referral | 52 weeks | HRSD; BDI | Fair
RCTs from systematic reviews | Ward et al., 2000^53^ and King et al., 2000^54^ | Depression or mixed anxiety depression | 36.8 (12.2) | 76% | 89% | PC | Referral | 52 weeks | BDI-21 | Fair
RCTs from systematic reviews | Williams et al., 2000^55^ and Frank et al., 2002^4^ | Dysthymia or minor depression | 71 (7.1) | 43% | 76% | PC | Screening and referral | 11 weeks | HSCL-D-20; HRSD | –
RCTs from primary literature searches | Barnhofer et al., 2009^56^ | MDD or subthreshold MDD | 41.9 (10.4) | 68% | NR | MH | Advertisement and referral | 8 weeks | BDI | Good
RCTs from primary literature searches | Laidlaw et al., 2008^57^ | MDD | 74.0 (8.0) | 73% | NR | PC | Referral | 26 weeks | BDI; GDS; HRSD | Fair
RCTs from primary literature searches | Mynors-Wallis et al., 2000^58^ | MDD | 34.5 (NR) | 78% | 93% | PC | Referral | 52 weeks | HRSD; BDI | Good
RCTs from primary literature searches | Nezu, 1986^59^ | MDD | 41.7 (12.8) | 81% | NR | MH | Advertisement | 26 weeks | BDI; MMPI-D | Fair
RCTs from primary literature searches | Simon et al., 2004^60^ and Simon et al., 2009^61^ | Antidepressant and depressive symptoms | 44.8 (15.5) | 74% | 80% | PC | Registry | 24 weeks | SCL | Good
RCTs from primary literature searches | Wilson, 1982^62^ | Self-report of depression | 38.8 (NR) | 66% | NR | MH | Advertisement | 26 weeks | BDI | Poor
RCTs from primary literature searches | Wilson, 1983^63^ | Self-report of depression | 39.5 (NR) | 80% | NR | MH | Advertisement | 8 weeks | BDI; HRSD | Fair

a Weeks since baseline assessment.

b Quality assessments were conducted for the seven newly identified RCTs, and in order to conduct the meta-analysis on studies of brief CBT, quality assessments were completed for two studies that had been included in the systematic reviews.

Abbreviations: BDI = Beck Depression Inventory, DHP = Diabetes Health Profile, DIS = Diagnostic Interview Schedule, GDS = Geriatric Depression Scale, GP = general practitioner, HRSD = Hamilton Rating Scale for Depression, HSLC-D = Headache Specific Locus of Control-Depression, MDD = major depressive disorder, MH = mental health, MMPI-D = Minnesota Multiphasic Personality Inventory Depression Scale, MOS-D = Medical Outcomes Study-Depression, NR = not reported, PC = primary care, PRIME-MD = Primary Care Evaluation of Mental Disorders Patient Health Questionnaire, RDC = Research Diagnostic Criteria, SADS-L = Schedule for Affective Disorders and Schizophrenia–Lifetime Version, SCAN = Schedules for Clinical Assessment in Neuropsychiatry, SCL = Symptom Checklist

Table 4 Summary of Intervention Characteristics

| Author, year | Therapy | # sessions | Session length | Session frequency | Modality | Therapist | Treatment fidelity? | Therapy completed [n (%)] | Control
RCTs from systematic reviews | Barrett et al., 2001^48^ and Frank et al., 2002^4^ | PST (n = 80) | 6 | 30 min | Ever 2 weeks | Individual | PhD psychologist | Yes | 64 (80%) | Placebo (n = 81)
RCTs from systematic reviews | Dowrick et al., 2000^5^ | PST (n = 128) | 6 | 30 min | NR | Individual | Psychologists, nurses, allied health professionals | Yes | 80 (63%) | Waitlist (n = 189)
RCTs from systematic reviews | Lynch et al., 1997^49^ | PST (n = 15) | 6 | 20 min | Weekly | Individual; telephone | Graduate students | No | 11 (73%) | Usual care (n = 14)
RCTs from systematic reviews | Lynch et al., 2004^50^ | PST (n = 18) | 6 | NR | Weekly | Individual; telephone | Nurses | Yes | NR | Usual care (n = 18)
RCTs from systematic reviews | Mynors-Wallis et al., 1995^51^ | PST (n = 30) | 6 | 30 min | Every 2 weeks | Individual | Experienced psychiatrist and trained GPs | No | 28 (93%) | Placebo (n = 30)
RCTs from systematic reviews | Scott et al., 1997^52^ | CBT (n = 24) | 6 | 30 min | Weekly | Individual | CBT therapist | Yes | 18 (75%) | Usual care (n = 24)
RCTs from systematic reviews | Ward et al., 2000^53^ and King et al., 2000^54^ | CBT (n = 63) | 6 | 50 min | Weekly | Individual | Experienced psychologists | Yes | 56 (89%) | Usual care (n = 67)
RCTs from systematic reviews | Williams et al., 2000^55^ and Frank et al., 2002^4^ | PST (n = 138) | 6 | 30 min | Every 2 weeks | Individual | PhD psychologist, social workers, master's-level counselors | Yes | 108 (78%) | Medication; placebo (n = 140)
RCTs from primary literature searches | Barnhofer et al., 2009^56^ | MBCT (n = 16) | 8 | 2 hours | Weekly | Group | MBCT therapists | Yes | 14 (88%) | TAU (n = 14)
RCTs from primary literature searches | Laidlaw et al., 2008^57^ | CBT (n = 21) | 8 | NR | NR | Individual | Master's-level psychologist | Yes | 20 (95%) | TAU (n = 23)
RCTs from primary literature searches | Mynors-Wallis et al., 2000^58^ | PST + Med. (n = 35) | 6 | 30 min | Every 2 weeks | Individual | Research practice nurse | No | 34 (97%) | Medication alone (n = 36)
RCTs from primary literature searches | Nezu, 1986^59^ | PST (n = 12) | 8 | 1.75 hours | Weekly | Group | Graduate students | Yes | 11 (92%) | Waitlist control (n = 9)
RCTs from primary literature searches | Simon et al., 2004^60^ and Simon et al., 2009^61^ | CBT+TCM (n = 195) | 8 | 35 min | Every ≈1.5 weeks^a^ | Individual; Telephone | Master's-level psychologist | No | 167 (86%) | TCM (n = 207)
RCTs from primary literature searches | Wilson, 1982^62^ | CBT (n ≈ 32)^b^ | 7 | 1 hour | Weekly | Individual | Graduate students | NR | 21 (66%) | Minimal contact^c^ (n ≈ 32)^b^
RCTs from primary literature searches | Wilson, 1983^63^ | CBT (n = 16) | 8 | 1 hour | Weekly | Individual | NR | No | 12 (75%) | Waitlist (n = 9)

a Weekly sessions for first 4 weeks, with frequency ranging from every 1 to 4 weeks for remaining four sessions.

b Estimate based on data provided in article.

c Minimal contact consisted of two 1-hour nondirective therapy sessions to coincide with medication refills.

Abbreviations: CBT = cognitive behavioral therapy (includes cognitive therapy and behavioral therapy), MBCT = mindfulness-based cognitive therapy, min = minutes, NR = not reported, PST = problem-solving therapy, TAU = treatment as usual, TCM = telephone case management

Of the 15 unique studies, 6 studies were conducted in the U.S., 6 in the U.K., 2 in Australia, and 1 recruited patients across several European countries. All studies were conducted with English-speaking patients. Patients were predominantly treated in primary care, with 11 trials taking place in a primary care setting, and 4 taking place in a mental health outpatient setting. Recruitment strategies varied such that participants were recruited via screening in five studies, referral from a provider in eight studies, advertisement in four studies, and registries in two studies; many trials used more than one recruitment method. Studies had varying diagnostic criteria for inclusion, with six trials specifically allowing for the inclusion of subthreshold depression (e.g., minor depression, adjustment disorder, depressive symptoms), five requiring a diagnosis of MDD, and the remaining four using other criteria (e.g., beginning antidepressant, self-report of depression).

The intervention in eight studies was PST; in six studies, CBT; and in one study, mindfulness-based cognitive therapy (MBCT). No trials of other psychotherapies using interventions of eight sessions or fewer were identified. Interventions were monitored for treatment fidelity in nine studies. Included studies most commonly measured depressive symptoms using the clinician-administered Hamilton Rating Scale for Depression (HRSD) and the self-report Beck Depression Inventory (BDI); only one study used neither of these measures. Even though no study extended treatment beyond eight sessions, followup duration was less than 6 months for seven studies and was 6 months or greater for eight studies. In all but one study, females outnumbered males by a ratio of at least 2 to 1. The average age for study participants ranged from 35 to 48 years of age in 13 of the 15 studies, with the 2 remaining studies having participants with average ages of 71 and 74 years of age. These two studies of elderly patients had mixed results: one found small to no benefit in elderly patients receiving PST for depression,55 and the other found significant and sustained benefit in elderly patients receiving CBT for depression.57 Most studies did not report race, and the six studies that did report race had heavily Caucasian samples. Only two study samples included any Veteran representation.48,55 In both samples, Veterans composed only a portion of the overall sample, and data on Veterans were not presented separately.

Quality assessments were conducted for the seven RCTs identified in the primary literature searches—one was rated as poor, three as fair, and three as good. Fair and poor studies were often rated as such due to inadequately addressing incomplete outcome data and not having outcome assessors who were blind to treatment assignment. In order to conduct the meta-analysis on studies of brief CBT, quality assessments were completed for two studies that had been included in the systematic reviews; both were rated as fair.

## KEY QUESTION 1 For primary care patients with depressive disorders, are brief, evidence-based psychotherapies with durations of up to eight sessions more efficacious than control for depressive symptoms (i.e., on self-report and/or clinician-administered measures) and quality of life (i.e., functional status and/or health-related quality of life)?

### Systematic Reviews

Cuijpers'45 systematic review of 15 RCTs found psychological treatment from a range of 6 to 16 sessions to be significantly more effective than control for treatment of depression in primary care (ES -0.31, 95% CI -0.45 to -0.17, NNT = 5.75). They found significantly larger effect sizes for studies in which participants were referred by their general practitioner (GP) (ES -0.43, 95% CI -0.58 to -0.28, NNT = 4.20) than for studies in which participants were recruited through systematic screening (ES -0.13, 95% CI -0.34 to 0.08, NNT = 13.51). The lower effect size for brief psychotherapy in the subgroup of primary care patients recruited through systematic screening was suggested as the reason why an initial comparison favored brief psychotherapy delivered in non–primary care settings (ES -0.67, 95% CI -0.75 to -0.58, NNT = 2.75) compared to brief psychotherapy delivered in primary care settings (ES -0.31, 95% CI -0.45 to -0.17, NNT = 5.75). The authors found no significant difference between studies in which participants were diagnosed with MDD (ES -0.21, 95% CI -0.42 to 0.00, NNT = 8.47) and studies in which participants' depressive symptomatology was alternatively determined (ES -0.40, 95% CI -0.56 to -0.23, NNT = 4.50). The multiple subgroup analyses conducted in this good-quality review allowed for the authors to present both robust and nuanced findings. In regard to psychotherapies with a fewer number of sessions, the authors found that, compared to control, psychotherapies of ≤ 6 sessions (n = 7) had a small but significant positive effect for the treatment of depression in primary care (ES -0.25, 95% CI -0.48 to -0.02, NNT = 7.14). HRQOL outcomes were not reported in this review.

Cape's46 meta-analysis of 34 studies examined efficacy in regard to treatment type and in regard to three diagnostic categories: anxiety, depression, and mixed depression and anxiety. For certain analyses, they combined patients with diagnoses in the latter two categories. They found smaller treatment effects when CBT was used for mixed depression and anxiety (ES -0.26, 95% CI -0.44 to -0.08) than for anxiety (i.e., predominantly panic disorder and generalized anxiety disorder; ES -1.06, 95% CI -1.31 to -0.80). They found similar small effect sizes for PST for depression and mixed depression and anxiety (ES -0.21, 95% CI -0.37 to -0.05) and for counseling for depression and mixed depression and anxiety (ES -0.32, 95% CI -0.52 to -0.11). The examination of different psychotherapies in three different diagnostic groups (i.e., depression, anxiety, and mixed depression and anxiety) was a particular strength of this review. In regard to brief psychotherapies specifically for patients with depression, the authors found a significant but small effect favoring brief CBT over usual GP care for depression (ES -0.33, 95% CI -0.60 to -0.06) and found a positive but statistically nonsignificant effect for PST over usual GP care (ES -0.26, 95% CI -0.49 to 0.03). No significant differences in efficacy were found between CBT and PST. HRQOL outcomes were not reported in this review.

### Primary Literature

Among the seven studies that we discovered were not included in the systematic reviews were two studies of PST, one of MBCT, and four of CBT. The 4 studies of CBT randomized 535 participants to treatment or control, whereas the 2 relevant studies of brief CBT covered in the systematic reviews randomized 178 participants to treatment or control. Because of the number of CBT trials not considered in the previous 2 systematic reviews, we conducted a meta-analysis of the 6 trials involving 713 patients to evaluate the effects of brief CBT (6 to 8 sessions) for depression.

For the 6 trials, study quality was rated as good (n = 1), fair (n = 4), or poor (n = 1). Studies enrolled patients with MDD (n = 2), depressive symptoms (n = 2), depression or mixed anxiety depression (n = 1), or patients with depressive symptoms who were starting an antidepressant (n = 1). Control conditions were treatment as usual in four of the six trials, and in two trials control conditions contained an additional therapeutic component beyond usual care.60,62 Care as usual in these trials was typically described as allowing the primary care provider their usual discretion in treating depression; some studies noted that this could include antidepressant medication, counseling, or referral, whereas other studies did not specify the range of options left open to providers.

Participants receiving brief CBT for depression were more likely than participants receiving a control treatment to have reduced symptoms of depression (ES -0.42, 95% CI -0.74 to -0.10), but treatment effects differed significantly across studies (Cochran Q = 13.74, p = 0.03, I^2^ = 56%) (Figure 3). The ES of -0.42 corresponds to an NNT of approximately 4.5. A funnel plot did not suggest significant publication bias, but with only six studies, this method has limited power to detect publication bias. To examine the moderate level of variability present, we conducted an influence analysis. In this analysis, the summary estimate ranged from -0.24 to -0.53, with the trial by Wilson63 having the greatest influence. This trial was the only one of the six CBT studies to use a waitlist control condition as the comparator. Based on a priori hypotheses of variables that might influence the effect size estimate, we conducted two sensitivity analyses: in the first, we removed poor-quality studies from the meta-analysis; in the second, we removed both poor-quality studies and studies that used nontherapeutic comparator conditions (e.g., waitlist) from the meta-analysis. In the meta-analysis with the poor-quality study removed,62 brief CBT for depression continued to be significantly more effective than control (ES -0.50, 95% CI -0.91 to -0.09), but treatment effects remained significantly heterogeneous (Cochran Q = 13.71, p = 0.008, I^2^ = 71%). With the poor-quality study62 and the study with a waitlist comparator63 removed, treatment effects of brief CBT for depression were smaller (ES -0.24, 95% CI -0.42 to -0.06) but homogeneous (Cochran Q = 1.44, p = 0.70, I^2^ = 0%). This effect size corresponds to an NNT of approximately eight. These results are highly consistent with both Cuijpers'45 and Cape's46 estimates of effect size for brief CBT for the treatment of depression.

Figure 3 Meta-analysis of Brief CBT for Depression

The 2 studies of PST identified in the primary literature searches and not included in the systematic reviews randomized 92 participants to treatment or control, whereas the 6 studies of PST covered in the systematic reviews randomized 881 participants. Thus, we did not conduct an updated meta-analysis for PST. The two studies of PST identified in the primary literature searches were conducted by Mynors-Wallis and colleagues58 and Nezu.59 In a good-quality trial involving 71 participants, Mynors-Wallis58 found that adding six sessions of PST to antidepressant medication did not significantly enhance outcomes over treatment with antidepressant medication alone after 12 weeks (60% recovered versus 67%). They also found that after 12 and 52 weeks antidepressant alone was not significantly different in effectiveness from PST alone. In a small, fair-quality trial, Nezu59 found eight sessions of PST to be significantly more effective in reducing depressive symptoms than either problem-focused therapy or a waitlist control at 8 weeks (t = 3.25, p < .01). These results are consistent with both Cape's46 and Cuijpers'45 conclusion that PST is an efficacious option for the treatment of depression.

No studies of MBCT were included in the systematic reviews. We identified a single good-quality study of MBCT that met our inclusion criteria.56 This study randomized 30 subjects with MDD or subthreshold depression, recruited from a mental health setting, and found 8 sessions of MBCT to be more efficacious than treatment as usual at reducing depressive symptoms at 8 weeks (F = 13.42, p = 0.001).

Quality of life was too infrequently reported across studies to synthesize into any quantitative analyses. The two studies of CBT from the present meta-analysis that included data on quality of life did not find significant differences on quality-of-life outcomes between participants in the CBT conditions compared to participants in the control conditions.53,57 No other trials from the studies identified via the primary literature searches included data on quality of life. The frequency with which data on quality of life were reported is considered in Key Question 4.

## KEY QUESTION 2 For primary care patients with depressive disorders treated with a brief, evidence-based psychotherapy, is there evidence that treatment effect may vary by the number of sessions delivered?

Cuijpers45 found a small difference in effect size between psychotherapies of six or fewer sessions (ES -0.25, 95% CI -0.48 to -0.02) compared to psychotherapies of seven or more sessions (ES -0.36, 95% CI -0.54 to -0.17), but confidence intervals overlapped. Should a more adequately powered meta-analysis be possible in the future, the means and confidence intervals surrounding these effect sizes leave room for the possibility of a clinically significant difference between brief and standard-duration psychotherapies.

Cape46 did not conduct a comparison based on number of psychotherapy sessions delivered, as their review was limited to therapies of fewer than 10 sessions in duration. Similarly, because the present review included only studies with eight or fewer sessions and there was little variability in session number (six to eight), an analysis of whether treatment effect varies by quantity of therapy sessions could not be conducted.

## KEY QUESTION 3 For psychotherapies demonstrating clinically significant treatment effects, what are the characteristics of treatment providers (i.e., type of provider and training), and what are the modalities of therapy (i.e., individual/ group, face-to-face/teletherapy/Internet-based)?

Of the 15 RCTs evaluating brief therapies, 13 used an individual psychotherapy format, and 2 relied on a group therapy format. Two of the individual PST treatments and one of the individual CBT treatments were conducted over the phone. PST treatment providers included psychologists in three studies, nurses in three studies, graduate students in two studies, and other health professionals in three studies (e.g., GPs, allied health professionals, social workers). CBT treatment providers included psychologists in three studies, graduate students in one study, and nonidentified professionals in two studies. The MBCT treatment provider had completed an internship under the supervision of an expert MBCT therapist. There was substantial variability in the level of detail provided about therapists' training. Most therapists were noted either as having previous experience in the intervention treatment model or as having been trained and supervised for study purposes by one of the study's investigators.

While the number of sessions ranged only from six to eight, there was substantial variance in the intensity at which psychotherapies were provided. The most intensive therapy, MBCT, required 2 hours per week for 8 weeks, whereas multiple PST protocols required only 30-minute sessions spaced approximately every other week. Although it would appear that the two were separated by a difference of only two sessions, the intensity was different because the MBCT protocol specified a total of 16 hours of treatment, whereas the PST protocols specified a total of only 3.5 hours (first session is typically 1 hour). Three of the CBT protocols consisted of 50- to 60-minute sessions, and two consisted of 30- to 35-minute sessions.

Quantitative syntheses to examine differences on the basis of treatment intensity, provider type, individual versus group, and telephone versus in-person could not be completed because there was not an adequate number of studies in each of these subgroups.

## KEY QUESTION 4 How commonly reported are the key clinical outcomes of quality of life, social functioning, occupational status, patient satisfaction, and adverse treatment effects in randomized trials of psychotherapy?

Neither of the two systematic reviews reported on quality of life, social functioning, occupational status, patient satisfaction, or adverse treatment effects. Of the 15 RCTs contained in this evidence report, 5 reported HRQOL, 5 reported social functioning, 0 reported occupational status, 2 reported patient satisfaction with treatment, and 1 reported adverse treatment effects (Table 5). The most commonly used measure of quality of life for studies that examined this clinical outcome was the SF-36. The one study that reported adverse treatment effects examined the side effects of taking psychotropic medication in tandem with psychotherapy.

Table 5 Key Clinical Outcome Measures

| Study | Quality of life | Social functioning | Occupational status | Patient satisfaction | Adverse treatment effects
RCTs from systematic reviews | Barrett et al, 2001^48^ and Frank et al., 2002^4^ | Yes, SF-36 | NR | NR | NR | NR
RCTs from systematic reviews | Dowrick et al., 2000^5^ | Yes, SF-36 | NR | NR | NR | NR
RCTs from systematic reviews | Lynch et al., 1997^49^ | NR | Yes | NR | NR | NR
RCTs from systematic reviews | Lynch et al., 2004^50^ | NR | NR | NR | NR | NR
RCTs from systematic reviews | Mynors-Wallis et al., 1995^51^ | NR | Yes | NR | Yes | NR
RCTs from systematic reviews | Scott et al., 1997^52^ | NR | NR | NR | NR | NR
RCTs from systematic reviews | Ward et al., 2000^53^ and King et al., 2000^54^ | Yes, EuroQoL | Yes | NR | NR | NR
RCTs from systematic reviews | Williams et al., 2000^55^ and Frank et al., 2002^4^ | Yes, SF-36 | NR | NR | NR | NR
RCTs from primary literature searches | Barnhofer et al., 2009^56^ | NR | NR | NR | NR | NR
RCTs from primary literature searches | Laidlaw et al., 2008^57^ | Yes, WHOQOL-BREF | Yes, social relationships | NR | NR | NR
RCTs from primary literature searches | Mynors-Wallis et al., 2000^58^ | NR | Yes, Social Adjustment Scale | NR | NR | Yes, medication side effects
RCTs from primary literature searches | Nezu, 1986^59^ | NR | NR | NR | NR | NR
RCTs from primary literature searches | Simon et al., 2004^60^ and Simon et al., 2009^61^ | NR | NR | NR | Yes | NR
RCTs from primary literature searches | Wilson, 1982^62^ | NR | NR | NR | NR | NR
RCTs from primary literature searches | Wilson, 1983^63^ | NR | NR | NR | NR | NR

Abbreviations: NR = not reported, WHOQOL = World Health Organization Quality of Life