# REFERENCES

1 Current depression among adults---United States, 2006 and 2008. MMWR Morb Mortal Wkly Rep. 2010;59(38):1229-35. [pmid: 20881934].
2 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). JAMA. 2003;289(23):3095-105. [pmid: 12813115].
3 Hankin CS, Spiro A 3rd, Miller DR, et al. Mental disorders and mental health treatment among U.S. Department of Veterans Affairs outpatients: the Veterans Health Study. Am J Psychiatry. 1999;156(12):1924-30. [pmid: 10588406].
4 Frank E, Rucci P, Katon W, et al. Correlates of remission in primary care patients treated for minor depression. Gen Hosp Psychiatry. 2002;24(1):12-9. [pmid: 11814529].
5 Dowrick C, Dunn G, Ayuso-Mateos JL, et al. Problem solving treatment and group psychoeducation for depression: multicentre randomised controlled trial. Outcomes of Depression International Network (ODIN) Group. BMJ. 2000;321(7274):1450-4. [pmid: 11110739].
6 Wang PS, Lane M, Olfson M, et al. Twelve-month use of Mental Health Services in the United States - Results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):629-640. [pmid: 15939840].
7 The Management of MDD Working Group: VA/DoD Clinical Practice Guideline for Management of Major Depressive Disorder (MDD). Washington, DC. Department of Veterans Affairs and Department of Defense. 2009. Available at: www.healthquality.va.gov/mdd/mdd_full09_c.pdf. January 12, 2011.
8 Oestergaard S, Moldrup C. Optimal duration of combined psychotherapy and pharmacotherapy for patients with moderate and severe depression: A meta-analysis. J Affect Disord. 2010.
9 Pampallona S, Bollini P, Tibaldi G, et al. Combined pharmacotherapy and psychological treatment for depression: a systematic review. Arch Gen Psychiatry. 2004;61(7):714-9. [pmid: 15237083].
10 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. 1996;53(10):924-32. [pmid: 8857869].
11 Gill D, Hatcher S. Antidepressants for depression in medical illness. Cochrane Database of Systematic Reviews. 2000;(4). Art. No.: CD001312.
12 Schulberg HC, Block MR, Madonia MJ, et al. The ‘usual care’ of major depression in primary care practice. Arch Fam Med. 1997;6(4):334-9. [pmid: 9225703].
13 Haas LJ. Handbook of primary care psychology. Oxford. New York. Oxford University Press. 2004.
14 DeLeon PH, R NP, Smedley BD. The future is primary care. Frank RG, McDaniel SH, Bray JH, Heldring M, editors. Primary care psychology. Washington. American Psychological Association. 2004:317-325.
15 Cummings NA. A history of behavioral healthcare: A perspective from a lifetime of involvement. Cummings NA, O'Donohue W, Hayes SC, Follette V, editors. Integrated behavioral healthcare: Positioning mental health practice with medical/surgical practice. San Diego. Academic Press. 2001:1-18.
16 Zeiss AM, Karlin BE. Integrating mental health and primary care services in the Department of Veterans Affairs health care system. J Clin Psychol Med Settings. 2008;15(1):73-8. [pmid: 19104957].
17 Post EP, Van Stone WW. Veterans Health Administration primary care-mental health integration initiative. N C Med J. 2008;69(1):49-52. [pmid: 18429567].
18 Backenstrass M, Joest K, Frank A, et al. Preferences for treatment in primary care: a comparison of nondepressive, subsyndromal and major depressive patients. Gen Hosp Psychiatry. 2006;28(2):178-80. [pmid: 16516070].
19 Chilvers C, Dewey M, Fielding K, et al. Antidepressant drugs and generic counselling for treatment of major depression in primary care: randomised trial with patient preference arms. BMJ. 2001;322(7289):772-5. [pmid: 11282864].
20 Raue P, Schulberg HC. Psychotherapy and patient preferences for the treatment of major depression in primary care. Henri MJ, editor. Trends in depression research. Hauppauge, NY. Nova Science Publishers. 2007:31-51.
21 van Schaik DJF, Klijn AFJ, van Hout HPJ, et al. Patients' preferences in the treatment of depressive disorder in primary care. Gen Hosp Psychiatry. 2004;26(3):184-189. [pmid: 15121346].
22 Trivedi RB, Nieuwsma JA, Williams JW Jr, et al. Evidence synthesis for determining the efficacy of psychotherapy for treatment resistant depression. Washington, DC. Department of Veterans Affairs. October. 2009. Available at: www.hsrd.research.va.gov/publications/esp/Depression-Q3.pdf. January 12, 2011.
23 Thase ME, Friedman ES, Biggs MM, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: a STAR*D report. Am J Psychiatry. 2007;164(5):739-52. [pmid: 17475733].
24 Lave JR, Frank RG, Schulberg HC, et al. Cost-effectiveness of treatments for major depression in primary care practice. Arch Gen Psychiatry. 1998;55(7):645-51. [pmid: 9672056].
25 Schoenbaum M, Unutzer J, Sherbourne C, et al. Cost-effectiveness of practice-initiated quality improvement for depression: results of a randomized controlled trial. JAMA. 2001;286(11):1325-30. [pmid: 11560537].
26 Schulberg HC, Raue PJ, Rollman BL. The effectiveness of psychotherapy in treating depressive disorders in primary care practice: clinical and cost perspectives. Gen Hosp Psychiatry. 2002;24(4):203-12. [pmid: 12100831].
27 Antonuccio DO, Thomas M, Danton WG. A cost-effectiveness analysis of cognitive behavior therapy and fluoxetine (prozac) in the treatment of depression. Behavior Therapy. 1997;28(2):187-210.
28 Vos T, Corry J, Haby MM, et al. Cost-effectiveness of cognitive-behavioural therapy and drug interventions for major depression. Aust N Z J Psychiatry. 2005;39(8):683-92. [pmid: 16050922].
29 Antonuccio DO, Danton WG, Denelsky GY. Psychotherapy Versus Medication for Depression - Challenging the Conventional Wisdom with Data. Professional Psychology-Research and Practice. 1995;26(6):574-585.
30 Fava GA, Rafanelli C, Grandi S, et al. Six-year outcome for cognitive behavioral treatment of residual symptoms in major depression. Am J Psychiatry. 1998;155(10):1443-5. [pmid: 9766780].
31 Hollon SD. Does cognitive therapy have an enduring effect?. Cognit Ther Res. 2003;27(1):71-75.
32 Perepletchikova F, Treat TA, Kazdin AE. Treatment integrity in psychotherapy research: analysis of the studies and examination of the associated factors. J Consult Clin Psychol. 2007;75(6):829-41. [pmid: 18085901].
33 Beck JS. Cognitive Therapy: Basics and Beyond. New York. Guilford Press. 1995.
34 Weissman MM, Markowitz JC, Klerman GL. Comprehensive Guide to Interpersonal Psychotherapy. New York. Basic Books. 2000.
35 Dewan MJ, Steenbarger BN, Greenberg RP, et al. Brief psychotherapies. The American Psychiatric Publishing textbook of psychiatry. 5th. Arlington, VA. American Psychiatric Publishing, Inc. 2008:1154-1170.
36 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776-82. [pmid: 18490690].
37 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].
38 Marinopoulos SS, Dorman T, Ratanawongsa N, et al. Effectiveness of Continuing Medical Education. Evidence Report/Technology Assessment No. 149. (Prepared by the Johns Hopkins Evidence-based Practice Center, under Contract No. 290-02-0018.) AHRQ Publication No. 07-E006. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. Available at: www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=erta149. January 12, 2011.
39 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. January 12, 2011.
40 Cohen J. Statistical power analysis for the behavioral sciences. 2nd. Hillsdale, N.J. L. Erlbaum Associates. 1988.
41 Kraemer HC, Kupfer DJ. Size of treatment effects and their importance to clinical research and practice. Biol Psychiatry. 2006;59(11):990-6. [pmid: 16368078].
42 Borenstein M. Introduction to meta-analysis. Chichester, West Sussex, U.K. ; Hoboken. John Wiley & Sons. 2009.
43 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
44 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
45 Cuijpers P, van Straten A, van Schaik A, et al. Psychological treatment of depression in primary care: a meta-analysis. Br J Gen Pract. 2009;59(559):e51-60. [pmid: 19192368].
46 Cape J, Whittington C, Buszewicz M, et al. Brief psychological therapies for anxiety and depression in primary care: meta-analysis and meta-regression. BMC Med. 2010;8(1):38. [pmid: 20579335].
47 Cuijpers P, van Straten A, Warmerdam L, et al. Psychological treatment of depression: a meta-analytic database of randomized studies. BMC Psychiatry. 2008;8:36. Available at: (www.psychotherapyrcts.org/index.php?id=3). January 12, 2011.
48 Barrett JE, Williams JW Jr, Oxman TE, et al. Treatment of dysthymia and minor depression in primary care: a randomized trial in patients aged 18 to 59 years. J Fam Pract. 2001;50(5):405-12. [pmid: 11350703].
49 Lynch DJ, Tamburrino MB, Nagel R. Telephone counseling for patients with minor depression: preliminary findings in a family practice setting. J Fam Pract. 1997;44(3):293-8. [pmid: 9071250].
50 Lynch D, Tamburrino M, Nagel R, et al. Telephone-based treatment for family practice patients with mild depression. Psychol Rep. 2004;94(3 Pt 1):785-92. [pmid: 15217028].
51 Mynors-Wallis LM, Gath DH, Lloyd-Thomas AR, et al. Randomised controlled trial comparing problem solving treatment with amitriptyline and placebo for major depression in primary care. BMJ. 1995;310(6977):441-5. [pmid: 7873952].
52 Scott C, Tacchi MJ, Jones R, et al. Acute and one-year outcome of a randomised controlled trial of brief cognitive therapy for major depressive disorder in primary care. Br J Psychiatry. 1997;171:131-4. [pmid: 9337947].
53 Ward E, King M, Lloyd M, et al. Randomised controlled trial of non-directive counselling, cognitive-behaviour therapy, and usual general practitioner care for patients with depression. I: clinical effectiveness. BMJ. 2000;321(7273):1383-8. [pmid: 11099284].
54 King M, Sibbald B, Ward E, et al. Randomised controlled trial of non-directive counselling, cognitive-behaviour therapy and usual general practitioner care in the management of depression as well as mixed anxiety and depression in primary care. Health Technol Assess. 2000;4(19):1-83.
55 Williams JW Jr, Barrett J, Oxman T, et al. Treatment of dysthymia and minor depression in primary care: A randomized controlled trial in older adults. JAMA. 2000;284(12):1519-26. [pmid: 11000645].
56 Barnhofer T, Crane C, Hargus E, et al. Mindfulness-based cognitive therapy as a treatment for chronic depression: A preliminary study. Behav Res Ther. 2009;47(5):366-73. [pmid: 19249017].
57 Laidlaw K, Davidson K, Toner H, et al. A randomised controlled trial of cognitive behaviour therapy vs treatment as usual in the treatment of mild to moderate late life depression. Int J Geriatr Psychiatry. 2008;23(8):843-50. [pmid: 18311844].
58 Mynors-Wallis LM, Gath DH, Day A, et al. Randomised controlled trial of problem solving treatment, antidepressant medication, and combined treatment for major depression in primary care. BMJ. 2000;320(7226):26-30. [pmid: 10617523].
59 Nezu AM. Efficacy of a social problem-solving therapy approach for unipolar depression. J Consult Clin Psychol. 1986;54(2):196-202. [pmid: 3700806].
60 Simon GE, Ludman EJ, Tutty S, et al. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: a randomized controlled trial. JAMA. 2004;292(8):935-42. [pmid: 15328325].
61 Simon GE, Ludman EJ, Rutter CM. Incremental benefit and cost of telephone care management and telephone psychotherapy for depression in primary care. Arch Gen Psychiatry. 2009;66(10):1081-9. [pmid: 19805698].
62 Wilson PH. Combined pharmacological and behavioural treatment of depression. Behav Res Ther. 1982;20(2):173-84. [pmid: 7073647].
63 Wilson PH. Comparative efficacy of behavioral and cognitive therapies of depression. Cognit Ther Res. 1983;7(2):111-124.
64 Anonymous. Uniform Mental Health Services in VA Medical Centers and Clinics VA Handbook 1160.01. Department of Veterans Affairs. Veterans Health Administration. Washington, DC. 2008. Available at: http://www1.va.gov/vhapublications/ViewPublication.asp?pub_ID=1762. January 12, 2011.