# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the Department of Veterans Affairs' Evidence-based Synthesis Program. The topic was selected after a formal topic nomination and prioritization process that included representatives from the Office of Mental Health Services, Health Services Research and Development, the Mental Health QUERI, and the Office of Mental Health and Primary Care Integration. The key research questions for this review were developed and refined after preliminary review of published peer-reviewed literature and consultation with VA and non-VA experts to select the patients and subgroups, interventions, outcomes, and settings addressed in this review.

The final key questions were as follows:

Key Question 1: For primary care patients with depressive disorders, are brief, evidence-based psychotherapies with durations of up to eight sessions more efficacious than control for depressive symptoms (i.e., on self-report and/or clinician-administered measures) and quality of life (i.e., functional status and/or health-related quality of life)?

Key Question 2: For primary care patients with depressive disorders treated with a brief, evidence-based psychotherapy, is there evidence that treatment effect may vary by the number of sessions delivered?

Key Question 3: For psychotherapies demonstrating clinically significant treatment effects, what are the characteristics of treatment providers (i.e., type of provider and training), and what are the modalities of therapy (i.e., individual/group, face-to-face/teletherapy/Internet-based)?

Key Question 4: How commonly reported are the key clinical outcomes of quality of life, social functioning, occupational status, patient satisfaction, and adverse treatment effects in randomized trials of psychotherapy?

We developed and followed a standard protocol for all steps of this review. Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic Framework

## OVERALL APPROACH

We utilized a combined approach, identifying and evaluating existing, good-quality systematic reviews and supplementing these reviews by searching for and evaluating original research not included in these reviews. We were guided in this process by published recommendations for conducting “complex systematic reviews,”36 which integrate findings from previous systematic reviews and findings from newly identified original research.

## SEARCH STRATEGY

We conducted our search strategy using the following three complementary approaches:

1. We searched for relevant, good-quality, English-language systematic reviews in MEDLINE (via PubMed), Embase, and PsycINFO from database inception through May 2010.
2. We used a well-documented Internet-accessible database of 243 psychotherapy trials (www.psychotherapyrcts.org/index.php?id=3), current through January 2010, as a data source for original research. Using this database, we searched for studies coded as including adults with a mood disorder who received face-to-face psychotherapy at a dose of eight or fewer therapy sessions.
3. To identify any recent literature not yet catalogued in the Internet-accessible database, we searched for English-language publications in MEDLINE (via PubMed), Embase, and PsycINFO from January 2009 (one year prior to the search date of the online database) through August 1, 2010.

We developed search strategies in consultation with a master librarian. The search terms and MeSH headings for the search strategies appear in Appendix A. We supplemented electronic searching by examining the bibliographies of included studies and systematic review articles.

## STUDY SELECTION

Using prespecified inclusion/exclusion criteria, two trained researchers reviewed the list of titles and abstracts, then selected articles, identified from any of the computerized and manual searches described above, for further review. Each article retrieved was reviewed using a brief screening form to determine eligibility. Systematic reviews were evaluated as “good,” “fair,” or “poor” using quality criteria (see Quality Assessment below) adapted from a previous report,37,38 and only good-quality reviews relevant to one of our study questions were retained. To be included in our evidence report, original research studies had to (1) be a randomized controlled trial (RCT), (2) compare an eligible psychotherapy of eight or fewer sessions to control, and (3) report effects on depression. Detailed eligibility criteria are described in Table 1.

Table 1 Summary of Inclusion and Exclusion Criteria

Study characteristic | Inclusion criteria | Exclusion criteria
Study design | Randomized controlled trial | None
Population | Adults with major depressive disorder (MDD), dysthymic disorder, or subthreshold (minor) depression in acute-phase treatment | Treatment-resistant depression, postpartum depression, premenstrual dysphoric disorder, bipolar disorder, seasonal affective disorder, or double depression (i.e., MDD and dysthymia)
Interventions | Cognitive behavioral therapy (CBT) (including cognitive therapy and behavior therapy), interpersonal therapy (IPT), problem-solving therapy (PST), mindfulness-based cognitive therapy (MBCT), cognitive behavioral analysis system of psychotherapy (CBASP), dialectical behavioral therapy (DBT), functional analytic psychotherapy (FAP), acceptance and commitment therapy (ACT), or short-term psychodynamic therapy with ≤ 8 planned sessions | Generic counseling, life review therapy, psychoeducational therapy, supportive therapy, bibliotherapy, or Internet-based psychotherapies
Comparators | Waitlist, attention control, usual care Antidepressant medication if intervention is psychotherapy and an antidepressant | Another psychotherapy
Setting | Outpatient general medical or general mental health | Study conducted outside of North America, Western Europe, New Zealand, or Australia
Outcome | Depressive symptoms using a validated instrument reported at ≥ 6 weeks after randomization | None

## DATA ABSTRACTION

For each newly identified primary research study, a trained researcher abstracted data from published reports into evidence tables (Appendix B). A second reviewer overread all data abstractions. We resolved disagreements by consensus among the first and second reviewer or by obtaining a third reviewer's opinion when consensus could not be reached. For eligible trials included in the two systematic reviews, we abstracted summary data from the reviews and supplemented these data by using the original publications when the reviews had incomplete information. We abstracted the following data: (1) study design and setting, (2) eligibility criteria, (3) exclusion criteria, (4) sample size, (5) demographics, (6) duration of followup, (7) depression clinical category, (8) intervention characteristics (e.g., type of therapy, mode, frequency, therapist), (9) comparator characteristics, (10) outcome measures, (11) results, and (12) adverse effects.

## QUALITY ASSESSMENT

For systematic reviews, we assessed the comprehensiveness of the search strategy, the description and appropriateness of inclusion criteria, whether primary studies were assessed for quality and the adequacy of the quality measure, the reproducibility of methods to assess studies, whether the results of relevant studies were combined appropriately, whether heterogeneity and publication bias were assessed, and whether the conclusions were supported by the data presented. Systematic reviews were rated “good” if the conclusions were supported by the data presented and there were no important study limitations. For original research studies, we assessed risk of bias using the key quality criteria described in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews,39 adapted for this specific topic. We abstracted data on adequacy of randomization and allocation concealment, comparability of groups at baseline, blinding, completeness of followup and differential loss to followup, whether incomplete data were addressed appropriately, validity of outcome measures, and conflict of interest. Using these data elements, we assigned a summary quality score of “good,” “fair,” or “poor” to individual RCTs.

## DATA SYNTHESIS

When good-quality systematic reviews were identified, we summarized the reviews' findings in narrative form. For original research studies that were not included in the systematic reviews, results were summarized descriptively in tables that include the study sample, intervention, comparator, duration of followup, and primary outcomes. We critically analyzed these studies to compare their characteristics, methods, and findings. We then evaluated whether the new evidence was likely to change estimates from prior reviews by considering the precision and stability of estimates from the original review, the number and size of the new studies relative to studies in the original review, the quality of the new studies, and the consistency in estimates and conclusions between the new evidence and the original reviews.39 After considering these issues, we updated prior meta-analyses when substantial new evidence was available and a new summary estimate might lead to different conclusions.

Because studies did not use a single common instrument to measure depression severity, our meta-analysis used effect sizes to summarize intervention effects. Effect sizes were calculated for each study by subtracting (at posttest) the average score of the control group from the average score of the experimental group and dividing the result by the pooled standard deviations (SDs) of the experimental and control groups. A negative effect size indicates a greater effect in the intervention group. For example, an effect size of -0.5 indicates that the mean decline in depression severity for the experimental group is half an SD greater than the mean decline in the control group. We applied this convention of a negative effect size indicating a greater intervention effect to our summary of existing systematic reviews, converting signs when necessary for consistency. Effect sizes are commonly interpreted as small (0.2), moderate (0.5), and large (≥ 0.80).40,41 To further aid interpretation of effect sizes, we converted these estimates to the number needed to treat (NNT) using the approach described by Kraemer.41 When studies used more than one validated instrument to assess depression severity, we used the mean of the effect sizes so that each study (or control group) contributed only one effect size. When means and SDs were not reported, we used other statistics (e.g., event rates) to calculate the effect size. For studies with more than one active eligible intervention (e.g., behavioral therapy and cognitive therapy arms) compared to a single control, we combined the intervention arms to avoid lack of independence that would be created if we entered each intervention into the analysis separately.42

Because considerable heterogeneity was expected, we used a random effects model to calculate a pooled mean effect size. We used the Q statistic and the I^2^ statistic to assess for heterogeneity in outcomes between studies. Because the Q statistic is underpowered, we consider a p < 0.10 as statistically significant. The I^2^ statistic is an indicator of heterogeneity in percentages. The importance of between-study heterogeneity was represented by the I^2^ statistic thresholds of 0% to 40% as likely not important, 30% to 60% as moderate, 50% to 90% as substantial, and 75% to 100% as considerable.43 Publication bias was tested by inspecting the funnel plot of the meta-analysis. This procedure is based on the expectation that if no publication bias is present, the effect sizes will be dispersed equally on either side of the overall effect. However, this method has limited power to detect publication bias, particularly when the number of included studies is few.

We conducted preplanned subgroup analyses by study quality and type of control group. For other study characteristics (e.g., sessions delivered, type of depression), there was not sufficient variability and numbers of studies to conduct subgroup analyses. We used an influence analysis, recomputing the pooled mean effect by removing one study at a time, to determine the influence of individual studies on the overall effect. We used the computer program Comprehensive Meta-analysis, Version 2.2.021 (www.meta-analysis.com/pages/about_us.html), to conduct all meta-analyses.

### Grading the Evidence for Each Key Question

We graded the strength of evidence for each key question using principles from the Grades of Recommendation, Assessment, Development, and Evaluation (GRADE) Working Group.44 This approach assesses the strength of evidence for each critical outcome by considering risk of bias, consistency, directness, precision, and publication bias. Other domains relevant to observational designs were not pertinent to our review. After considering each domain, a summary rating of “high,” “moderate,” “low,” or “insufficient” strength of evidence was assigned after discussion by two reviewers (Table 2).

Table 2 Definitions for Strength of Evidence Rating

Strength of evidence rating | Definition
High | Further research is very unlikely to change our confidence in the estimate of effect
Moderate | Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate
Low | Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate
Insufficient | Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect

## PEER REVIEW

A draft version of this report was sent to five peer reviewers. Their comments and our responses are presented in Appendix C.