# INTRODUCTION

Depressive disorders present a major public health concern. The prevalence of current depression among U.S. adults is 6.6%,1 affecting up to 16 to 18% of the population over their lifetime.2 High prevalence rates have also been noted in the Veteran population,3 and particularly high rates have been found in primary care settings.4 Although primary care physicians treat a high proportion of patients with depressive disorders,5 the treatment of depression in primary care tends to be variable and suboptimal.6 Because of this, it is a public health priority to identify treatments for depression that are effective, evidence-based, and suitable for dissemination in primary care.

The two evidence-based, first-line interventions for depression recommended by VA/Department of Defense (DoD) guidelines are pharmacotherapy and/or psychotherapy.7 Based on several systematic reviews showing small-to-moderate benefit, the guideline recommends several classes of antidepressants as first-line therapy. Among psychotherapies, cognitive behavioral therapy (CBT), interpersonal psychotherapy (IPT) and problem-solving therapy (PST) are recommended as first-line treatment. For CBT and IPT, 16 to 20 sessions are recommended. Other psychotherapies are recommended for specific clinical situations, such as dialectical behavioral therapy (DBT), in combination with antidepressants for older adults with chronic major depressive disorder (MDD). In general, the evidence suggests that pharmacotherapy and psychotherapy are individually efficacious treatments and that there can be additive clinical benefit when these treatments are used in tandem.8,9

Despite persuasive evidence of effectiveness for both pharmacotherapy and psychotherapy in the treatment of depression, medication remains by far the most commonly utilized intervention in primary care settings.10-12 However, there has been a growing interest in and commitment to the integration of psychotherapy and other mental health services into primary care settings,13-15 perhaps most notably within the Veterans Health Administration.16,17 Providing primary care patients with the option of receiving psychotherapy for their depression is an important objective for multiple reasons: there are many patients who, given the option, prefer psychotherapy to medication;18-21 there is a need to provide alternative treatments for patients who do not improve on or cannot tolerate antidepressant medication;22,23 and there may be unique benefits from psychotherapy in terms of costs24-28 and relapse prevention.29-31

While there is good rationale for increasing the availability of psychological treatments for depression in primary care, there are also substantial barriers to incorporating psychotherapies into this setting. As with the prescription of antidepressant medication, there is a significant problem in delivering psychotherapy at the proper dose and with fidelity to the treatment model.6,32 There are also a number of barriers to implementing psychotherapies in primary care that are distinct from barriers to providing effective pharmacological treatment. These barriers involve such pragmatic concerns as finding space in primary care clinics where psychotherapy can be provided in confidentiality and securing an adequate workforce with the proper training to meet the demand for psychotherapy.

Perhaps the most significant barrier to providing psychotherapies in primary care settings is that, unlike pharmacological treatment, many empirically supported psychotherapy treatment protocols consist of at least 12 to 16 weekly 1-hour sessions.33,34 While this treatment duration is much abbreviated compared with older approaches to the provision of psychotherapy,35 it is arguably still too intensive for reliable implementation in primary care settings.

Recognizing that time and resource constraints present important barriers to effectively implementing standard-duration psychotherapies (i.e., 12 to 20 sessions) for depression in primary care settings, this report evaluates whether psychotherapy for depression can be efficacious after a period of 8 or fewer sessions—what we define as brief psychotherapy. In examining the evidence on brief psychotherapies for depression, this report also aims to address issues of the amount of training necessary to deliver psychotherapeutic treatment effectively and the availability of data on key clinical outcomes like social functioning and satisfaction with treatment. Effectively treating depression in primary care patients is an important public health priority. With that in mind, this report endeavors to examine whether brief psychotherapies are often tailored specifically for primary care settings and are efficacious for the treatment of depression.