# FUTURE RESEARCH

The present review confirmed that brief psychotherapies (i.e., ≤ 8 sessions), such as brief CBT and brief PST, are efficacious as acute-phase treatments for depression. However, many questions remain to be answered about the effectiveness of brief psychotherapy. First, future research should rigorously test whether brief psychotherapies are of comparable efficacy to standard-duration psychotherapies (i.e., 12 to 20 sessions). This question was not directly tested by any trials in our review. Hence, our analysis of this question relied on pooled comparisons of various treatment durations from different trials, a method that is vulnerable to multiple confounders. Future research should include RCTs that compare psychotherapies that differ according to the number of sessions.

Existing research has also been limited by an inadequate consideration of patient outcomes. Accordingly, we advise future researchers to assess longer term outcomes after the conclusion of brief psychotherapies (e.g., 6 months or longer). Researchers should also assess a broader set of outcomes, such as social functioning, occupational status, and quality of life, instead of solely assessing depression severity. Quality-of-life measures are especially desirable as these allow for the computation of cost-effectiveness and cost-utility ratios, which are crucial for informing policy decisions.

Another priority for future research should be to evaluate whether the administration of brief psychotherapies in primary care settings actually produces the benefits that proponents claim. These include claims that (1) brief psychotherapies provided in the primary care context reduce the stigma of receiving treatment for mental health problems, (2) providing brief psychotherapies broadens the population that will initiate and complete treatment by placing a lower time burden on patients, and (3) brief psychotherapies increase the cost-effectiveness of psychotherapy. Proponents have also claimed that brief psychotherapies can be used to prevent the development of MDD in at-risk patients, such as patients with minor depression. These hypotheses should be tested empirically.

Finally, it is crucial to assess which types of brief psychotherapies can be provided with high treatment fidelity and efficacy and by which types of providers. Additional studies are needed to determine whether brief psychotherapies other than CBT and PST are efficacious. Also, an important consideration to be assessed is patient preferences for different treatment modalities and providers. Further, more research is needed to determine which providers are best suited to provide brief therapies. In the VA, these providers could include not only mental health professionals like psychologists, psychiatrists, and social workers but also appropriately trained and supervised registered nurses, nurse practitioners, physician's assistants, primary care physicians, and chaplains.

The VA has been a leader in fostering models of integrated primary care and mental health care, and in doing so, the VA is in a unique position to address many of the previously stated research needs within the context of integrated health care teams.