# DISCUSSION

Based on our complex systematic review of two recent literature reviews and seven additional RCTs not considered in these previous reviews, the collective evidence suggests that six to eight sessions of brief CBT or PST for acute-phase treatment in primary care are more efficacious than usual care, but effects are modest. However, insofar as usual care consists of treatments that are intended to be effective and that may in some cases be “best practice” treatments, usual care could represent a more potent control condition than placebo controls used in antidepressant trials. Also, there is some evidence to indicate that brief psychotherapy may be more efficacious when patients are referred at the discretion of their primary care provider than when patients are selected for treatment on the basis of systematic depression screening. We conclude that brief psychotherapy may prove an efficacious treatment option for a number of patients with depression in VA primary care settings. Because the reviewed studies contained little Veteran representation, relied heavily on samples of predominantly middle-aged Caucasian females, and frequently excluded patients with complex or comorbid psychiatric conditions, additional research is needed to more definitively confirm the effectiveness of brief psychotherapy for depression in the Veteran population (Key Question 1).

Whether brief psychotherapies significantly differ in efficacy from standard-duration psychotherapies (12 to 20 sessions) is a question that we could not directly address given the limited range of session duration (6 to 8) in the 15 studies included in this review. Cuijpers' (2009) review45 found no statistically significant differences between psychotherapies delivered in six or fewer sessions compared to psychotherapies delivered over seven or more sessions; however, the wide confidence intervals for effect sizes of brief and standard-duration psychotherapies leave open the possibility of clinically significant differences (Key Question 2).

Our review found that brief psychotherapies have been provided by an array of trained health care professionals, including non–mental health professionals. The efficacious treatments included in this review were provided not only by psychologists but also by graduate students, nurses, general practitioners, and other allied health professionals who had received training and supervision specific to the intervention being conducted. Details about training were sparse, meaning that the degree of training necessary to replicate studies' results is uncertain (Key Question 3). Finally, we discovered that effects on occupational status, patient satisfaction with treatment, and adverse treatment effects were seldom reported; HRQOL and social functioning were more commonly reported but still only considered in less than half the trials examined in this review (Key Question 4).

Depressive disorders cause enormous human suffering and impose a high economic burden. Ensuring access to evidence-based treatments for Veterans is critical to the VA mission. The current emphasis on evidence-based care management in the VA has the potential to significantly enhance the usual care of depression in VA primary care settings, and the Primary Care/Mental Health Integration program in the VA represents an important organizational strategy to improve access and the quality of mental health care. If the VA were to expand its capability to provide brief psychotherapy for primary care patients in the acute phase of depression, this too has the potential to improve access and quality. Fewer sessions would mean that the same workforce could provide treatment to a larger number of patients, potentially more cost-effectively. In addition, clinicians from a variety of disciplines, if given adequate training and under appropriate supervision, may be able to provide brief therapies, further expanding access. Although the exact training was often incompletely described, many studies used focused training with non–mental health specialists, followed by fidelity monitoring to ensure quality. Fidelity monitoring may be a key component of replicating the positive treatment effects, particularly with generalist clinicians. Within the VA, a range of providers could be considered, including nurses, nurse practitioners, primary care physicians, social workers, and chaplains. However, given the current nursing shortage and high demands on primary care physicians, any change or expansion in roles would need to be considered carefully.

If non–mental health professionals were to assume the role of providing brief therapies, patients should be screened carefully for those without high complexity, and oversight should be provided by qualified mental health professionals to ensure the safety of the patient. In the VA, integrated primary care/mental health teams often consist of primary care clinicians, psychiatrists, psychologists, and nurses and may provide an ideal context and support system in which to implement such a model.

One of our key questions was to assess how frequently key clinical outcomes were assessed. Review results revealed a striking lack of consistency in assessing and reporting important outcome measures. Of the 15 RCTs contained in this review, only 5 reported HRQOL, 5 reported social functioning, 0 reported of occupational status, 2 reported patient satisfaction with treatment, and 1 reported adverse treatment effects. Evaluating the efficacy of treatment is clearly important; however, without measuring key clinical outcomes like quality of life, social functioning, and occupational functioning, we constrict ourselves to understanding only a very limited range of how psychotherapies can impact mental and physical health.

## STRENGTHS AND LIMITATIONS

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, careful quality assessment, and rigorous quantitative synthesis methods. For the included systematic reviews, we verified outcomes reported and supplemented the descriptions of included trials by abstracting missing data from the primary publications. We also combined a narrative review of recent, good-quality systematic reviews with new meta-analyses when indicated. This approach allowed us to capitalize on the strengths and often detailed analyses performed in existing reviews while updating those results to include the most recent and relevant studies.

However, several questions still remain. First, the efficacy of brief psychotherapy modalities other than CBT and PST could not be determined. Although we had hoped to review a variety of interventions, CBT and PST were the only treatments in our review for which more than one trial had been completed. Second, it is not clear if efficacy differs by the number of treatment sessions. This was a key question for our review that we were unable to answer. For CBT and PST, six to eight sessions has a small, beneficial effect compared to usual care, but a lower bound or dose-response relationship could not be determined. Third, the studies included in this review were composed primarily of Caucasian, middle-aged females. This limits applicability to the VA and to many other segments of society. Research is needed to evaluate whether results are applicable across diverse populations. Fourth, it remains unclear whether the efficacy of brief psychotherapies varies according to depression severity (i.e., mild, moderate, severe). Fifth, major intervention outcomes (e.g., quality of life, social functioning, occupational status) are measured too infrequently. While these outcomes are often considered “secondary,” they are critical in evaluating the safety and generalizability of treatments for real-world practice.

Despite these limitations, it appears that brief psychotherapy is effective in primary care settings in the acute-phase treatment of depression. Increasing the availability of psychotherapy, either through enlarging the pool of mental health professionals or by training non–mental health professionals, will advance the VA toward its mission of providing easy access to care for Veterans.64

## CONCLUSIONS

We identified two systematic reviews and 15 trials of brief psychotherapy (i.e., ≤ 8 sessions) for depression, encompassing 1716 patients with MDD or depressive symptomatology. Both systematic reviews concluded that brief CBT and PST are efficacious for the acute-phase treatment of depression in primary care. This conclusion was corroborated by our analyses that included seven additional studies. Table 6 summarizes the strength of evidence for the question of whether brief psychotherapies are more efficacious than control for depressive symptoms. GRADE criteria were not applicable to the other key questions.

Table 6 Summary of the Strength of Evidence for Key Question 1

Number of studies (subjects) | Domains pertaining to strength of evidence | | | | Magnitude of effect and strength of evidence
| Risk of Bias: Design/Quality | Consistency | Directness | Precision | Standardized mean difference (95% CI)
Key Question 1: Efficacy of brief psychotherapies
Brief CBT 6 (713) | RCTs/Fair | Consistent | Direct | Some imprecision | -0.42 (-0.10 to -0.74) Moderate
Brief PST 8 (973) | RCTs/Good | Consistent | Direct | Some imprecision | -0.26 (-0.49 to -0.30) Moderate
MBCT 1 (30) | RCT/Good | NA | Direct | Serious imprecision | Low
Other therapies | NA | NA | NA | NA | Insufficient