# ACRONYMS AND ABBREVIATIONS

ACT: acceptance and commitment therapy
AE: adverse effects
BDI-II: Beck Depression Inventory-II
CBASP: cognitive behavioral analysis system of psychotherapy
CBT: cognitive behavioral therapy
CES-D: Center for Epidemiologic Studies-Depression
CI: confidence interval
CM: care management
DBT: dialectical behavioral therapy
DHP: Diabetes Health Profile
DIS: Diagnostic Interview Schedule
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders
FAP: functional analytic psychotherapy
GP: general practitioner
HAM-D: Hamilton Depression Scale
HRSD: Hamilton Rating Scale for Depression
HSLC-D: Headache Specific Locus of Control-Depression
IPT: interpersonal therapy
LOCF: last observation carried forward
MBCT: mindfulness-based cognitive therapy
MDD: major depressive disorder
MDE: major depressive episode
MH: mental health
MMPI-D: Minnesota Multiphasic Personality Inventory-Depression
MMSE: Mini Mental State Examination
MOS-D: Medical Outcomes Study-Depression
N or n: number
NA: not applicable
NNT: number needed to treat
NR: not reported
NS or ns: not significant
OR: odds ratio
p: probability
PC: primary care
PFT: problem-focused therapy
PHQ: Patient Health Questionnaire
PRIME-MD: Primary Care Evaluation of Mental Disorders
PST: problem-solving treatment
PTSD: posttraumatic stress disorder
RCT: randomized controlled trial
RDC: Research Diagnostic Criteria
Rx: medicine prescription
SADS-L: Schedule for Affective Disorders and Schizophrenia-Lifetime Version
SCAN: Schedules for Clinical Assessment in Neuropsychiatry
SCL: Symptom Checklist
SD: standard deviation
SE: standard error
ST: standard treatment
TAU: treatment as usual
vs: versus
WHOQOL: World Health Organization Quality of Life
wk: week or weeks
WLC: waitlist control
yr: year or years