# EXCLUDED STUDIES

All studies listed below were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows the table

Reference | Population not appropriate | Intervention not of interest | Comparator not appropriate | Not SR or RCT | > 8 therapy sessions planned | Main outcome not of interest
Abbass-Allen, 2006 (535) | X
Abraham, 1992 (656) | | | | | X
Alexopoulis, 2003 (657) | | | | | X
Anonymous, 2010 (733) | | | | X
Arean, 1993 (658) | | | | | X
Barrera, 1979 (685) | | | X
Bedi, 2000 (686) | | | X
Bee, 2010 (708) | X
Bell, 2009 (458) | X
Beutler, 1987 (659) | | | | | X
Boer, 2005 (575) | X
Bortolotti, 2008 (71) | | X
Campbell, 1992 (660) | | | | | | X
Catalan, 1991 (661) | X
Ciechanowski, 2004 (662) | | | X
Coelho, 2007 (447) | X
Cole, 2008 (74) | X
Comas-Diaz (702) | | | X
Cuijpers, 2008 (469) | X
Cuijpers, 2010 (31) | | X
Cuijpers, 2010 (467) | | X
Cuijpers, 2007 (137) | X
Cuijpers, 2008 (76) | | | | X
Cuijpers, 2007 (462) | X
de Mello, 2005 (355) | | | | | X
Dhooper, 1993 (736) | | X
Doorenbos, 2005 (663) | X
Dozios, 2009 (709) | | | | | X
Driessen, 2010 (510) | X
Ekers, 2008 (345) | X
Fleming, 1980 (687) | | | X
Floyd, 2004 (665) | | | | | X
Fry, 1984 (737) | | | | | X
Fuchs, 1997 (688) | | X
Gardner, 1981 (689) | | | X
Godbole, 1973 (667) | X
Hamdan-Mansauer, 2009 (711) | | | | | X
Haringsma, 2006 (668) | | | | | X
Hegerl, 2010 (713) | | | | | X
Hogg, 1988 (744) | | | X
Holland, 2009 (714) | X
Hsu, 2009 (715) | | X
Huffiziger, 2009 (716) | | | | | | X
Hynninen, 2010 (718) | X
Jarvik, 1982 (669) | | | X
Kanter, 2010 (719) | | | | | X
Katon, 2004 (672) | X
Konnert, 2009 (720) | X
Kotova, 2005 (342) | | | | | X
LaPointe, 1980 (748) | X
Latour, 1994 (738) | | X
Lichtenberg, 1996 (739) | X
Lynch, 2010 (33) | X
Mackin, 2005 (177) | | X
Mazzuchelli, 2009 (368) | | | X
McCurren, 1999 (673) | | X
McKnight, 1992 (740) | | X
McNaughton, 2009 (21) | | X
Miranda, 2003 (691) | | | X
Mohr, 2008 (498) | | X
Montgomery, 2010 (372) | X
Mynor-Wallis, 1997 (674) | X
Nezu, 1989 (678) | | | | | X
Nezu, 2003 (677) | X
Oranta, 2010 (722) | X
Pace, 1993 (704) | X
Parker, 2007 (517) | | | | X
Pecheur, 1984 (706) | | | X
Peden, 2000 (697) | X
Peng, 2009 (19) | | | | | X
Petersen, 2010 (734) | X
Pigeon, 2009 (723) | X
Powers, 2009 (358) | X
Reynolds, 1999 (680) | X
Sallis, 1983 (741) | | | | | X
Serfaty, 2009 (724) | | | | | X
Shaw, 1977 (698) | | X
Sirey, 2005 (692) | | X
Stulz, 2010 (728) | | | | X
Taylor, 1977 (707) | | | X
Thompson, 1984 (742) | | | | X
Thompson, 1987 (743) | | | | | X
Tsang, 2008 (93) | | X
Uebelacker, 2009 (729) | | | | X
Unutzer, 2002 (681) | | | X
Van Calker, 2009 (730) | X
Watkins, 2009 (693) | | X
Watkins, 2009 (732) | | X
Warmerdam, 2010 (731) | | X
Wierzbicki, 1987 (746) | | | X
Wood, 1997 (682) | X
Yang, 2009 (696) | X
Zerhusen, 1991 (683) | | | | | X

## LIST OF EXCLUDED STUDIES

Abbass Allan A, Hancock Jeffrey T, Henderson J, et al. Short-term psychodynamic psychotherapies for common mental disorders. Cochrane Database of Systematic Reviews. 2006;(4).
Abraham IL, Neundorfer MM, Currie LJ. Effects of group interventions on cognition and depression in nursing home residents. Nurs Res. 1992;41(4):196-202. [pmid: 1383947].
Alexopoulos GS, Raue P, Arean P. Problem-solving therapy versus supportive therapy in geriatric major depression with executive dysfunction. Am J Geriatr Psychiatry. 2003;11(1):46-52. [pmid: 12527539].
Anonymous. Cognitive Behavioral Therapy Effective for Depressed Elderly. J Natl Med Assoc. 2010;102(4):358.
Arean PA, Perri MG, Nezu AM, et al. Comparative effectiveness of social problem-solving therapy and reminiscence therapy as treatments for depression in older adults. J Consult Clin Psychol. 1993;61(6):1003-10. [pmid: 8113478].
Barrera M Jr. An evaluation of a brief group therapy for depression. J Consult Clin Psychol. 1979;47(2):413-5. [pmid: 469095].
Bedi N, Chilvers C, Churchill R, et al. Assessing effectiveness of treatment of depression in primary care. Partially randomised preference trial. Br J Psychiatry. 2000;177:312-8. [pmid: 11116771].
Bee PE, Bower P, Gilbody S, et al. Improving health and productivity of depressed workers: a pilot randomized controlled trial of telephone cognitive behavioral therapy delivery in workplace settings. Gen Hosp Psychiatry. 2010;32(3):337-40. [pmid: 20430241].
Bell AC, D'Zurilla TJ. Problem-solving therapy for depression: A meta-analysis. Clin Psychol Rev. 2009;29(4):348-353. [pmid: 19299058].
Beutler LE, Scogin F, Kirkish P, et al. Group cognitive therapy and alprazolam in the treatment of depression in older adults. J Consult Clin Psychol. 1987;55(4):550-6. [pmid: 3624611].
Boer Peter CAM, Wiersma D, Russo S, et al. Paraprofessionals for anxiety and depressive disorders. Cochrane Database of Systematic Reviews. 2005;(2).
Bortolotti B, Menchetti M, Bellini F, et al. Psychological interventions for major depression in primary care: a meta-analytic review of randomized controlled trials. Gen Hosp Psychiatry. 2008;30(4):293-302. [pmid: 18585531].
Campbell JM. Treating depression in well older adults: use of diaries in cognitive therapy. Issues Ment Health Nurs. 1992;13(1):19-29. [pmid: 1737700].
Catalan J, Gath DH, Anastasiades P, et al. Evaluation of a brief psychological treatment for emotional disorders in primary care. Psychol Med. 1991;21(4):1013-8. [pmid: 1780394].
Ciechanowski P, Wagner E, Schmaling K, et al. Community-integrated home-based depression treatment in older adults: a randomized controlled trial. JAMA. 2004;291(13):1569-77. [pmid: 15069044].
Coelho HF, Canter PH, Ernst E. Mindfulness-based cognitive therapy: Evaluating current evidence and informing future research. J Consult Clin Psychol. 2007;75(6):1000-1005. [pmid: 18085916].
Cole MG. Brief interventions to prevent depression in older subjects: a systematic review of feasibility and effectiveness. Am J Geriatr Psychiatry. 2008;16(6):435-43. [pmid: 18515687].
Comas-Diaz L. Effects of cognitive and behavioral group treatment on the depressive symptomatology of Puerto Rican women. J Consult Clin Psychol. 1981;49(5):627-32. [pmid: 7287971].
Cuijpers P, van Straten A, Andersson G, et al. Psychotherapy for depression in adults: A meta-analysis of comparative outcome studies. J Consult Clin Psychol. 2008;76(6):909-922. [pmid: 19045960].
Cuijpers P, van Straten A, Bohlmeijer E, et al. The effects of psychotherapy for adult depression are overestimated: a meta-analysis of study quality and effect size. Psychol Med. 2010;40(2):211-23. [pmid: 19490745].
Cuijpers P, van Straten A, Schuurmans J, et al. Psychotherapy for chronic major depression and dysthymia: A meta-analysis. Clin Psychol Rev. 2010;30(1):51-62. [pmid: 19781837].
Cuijpers P, van Straten A, Warmerdam L. Problem solving therapies for depression: a meta-analysis. Eur Psychiatry. 2007;22(1):9-15. [pmid: 17194572].
Cuijpers P, van Straten A, Warmerdam L, et al. Psychological treatment of depression: a meta-analytic database of randomized studies. BMC Psychiatry. 2008;8:36. Available at: (http://www.psychotherapy-rcts.org/index.php?id=3). 10, 2010.
Cuijpers P, van Straten FSA. Psychological treatments of subthreshold depression: A meta-analytic review. Acta Psychiatr Scand. 2007;115(6):434-441. [pmid: 17498154].
de Mello MF, de Jesus Mari J, Bacaltchuk J, et al. A systematic review of research findings on the efficacy of interpersonal therapy for depressive disorders. Eur Arch Psychiatry Clin Neurosci. 2005;255(2):75-82. [pmid: 15812600].
Dhooper S, Green S, Huff M, et al. Efficacy of a group approach to reducing depression in nursing home elderly residents. Journal of Gerontological Social Work. 1993;20(3/4):87-100.
Doorenbos A, Given B, Given C, et al. Reducing symptom limitations: a cognitive behavioral intervention randomized trial. Psychooncology. 2005;14(7):574-84. [pmid: 15643674].
Dozois DJ, Bieling PJ, Patelis-Siotis I, et al. Changes in self-schema structure in cognitive therapy for major depressive disorder: a randomized clinical trial. J Consult Clin Psychol. 2009;77(6):1078-88. [pmid: 19968384].
Driessen E, Cuijpers P, de Maat SCM, et al. The efficacy of short-term psychodynamic psychotherapy for depression: A meta-analysis. Clin Psychol Rev. 2010;30(1):25-36. [pmid: 19766369].
Ekers D, Richards D, Gilbody S. A meta-analysis of randomized trials of behavioural treatment of depression. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2008;38(5):611-623.
Fleming BM, Thornton DW. Coping skills training as a component in the short-term treatment of depression. J Consult Clin Psychol. 1980;48(5):652-4. [pmid: 7410667].
Floyd M, Scogin F, McKendree-Smith NL, et al. Cognitive therapy for depression: a comparison of individual psychotherapy and bibliotherapy for depressed older adults. Behav Modif. 2004;28(2):297-318. [pmid: 14997954].
Fry P. Cognitive Training and Cognitive-Behavioral Variables in the Treatment of Depression in the Elderly. Clin Gerontol. 1984;3(1):25-44.
Fuchs CZ, Rehm LP. A self-control behavior therapy program for depression. J Consult Clin Psychol. 1977;45(2):206-15. [pmid: 850005].
Gardner P, Oei TP. Depression and self-esteem: an investigation that used behavioral and cognitive approaches to the treatment of clinically depressed clients. J Clin Psychol. 1981;37(1):128-35. [pmid: 7204587].
Godbole A, Verinis JS. Brief psychotherapy in the treatment of emotional disorders in physically ill geriatric patients. Gerontologist. 1974;14(2):143-8. [pmid: 4470475].
Hamdan-Mansour AM, Puskar K, Bandak AG. Effectiveness of cognitive-behavioral therapy on depressive symptomatology, stress and coping strategies among Jordanian university students. Issues Ment Health Nurs. 2009;30(3):188-96. [pmid: 19291496].
Haringsma R, Engels GI, Cuijpers P, et al. Effectiveness of the Coping With Depression (CWD) course for older adults provided by the community-based mental health care system in the Netherlands: a randomized controlled field trial. Int Psychogeriatr. 2006;18(2):307-25. [pmid: 16255838].
Hegerl U, Hautzinger M, Mergl R, et al. Effects of pharmacotherapy and psychotherapy in depressed primary-care patients: a randomized, controlled trial including a patients' choice arm. Int J Neuropsychopharmacol. 2010;13(1):31-44. [pmid: 19341510].
Hogg J, Deffenbacher J. A comparison of cognitive and interpersonal-process group therapies in the treatment of depression among college students. Journal of Counseling Psychology. 1988;35(3):304-310.
Holland JM, Currier JM, Gallagher-Thompson D. Outcomes from the Resources for Enhancing Alzheimer's Caregiver Health (REACH) program for bereaved caregivers. Psychol Aging. 2009;24(1):190-202. [pmid: 19290751].
Hsu YC, Wang JJ. Physical, affective, and behavioral effects of group reminiscence on depressed institutionalized elders in Taiwan. Nurs Res. 2009;58(4):294-9. [pmid: 19609181].
Huffiziger S, Kuehner C. Rumination, distraction, and mindful self-focus in depressed patients. Behav Res Ther. 2009;47(3):224-30. [pmid: 19166993].
Hynninen MJ, Bjerke N, Pallesen S, et al. A randomized controlled trial of cognitive behavioral therapy for anxiety and depression in COPD. Respir Med. 2010;104(7):986-94. [pmid: 20346640].
Jarvik LF, Mintz J, Steuer J, et al. Treating geriatric depression: a 26-week interim analysis. J Am Geriatr Soc. 1982;30(11):713-7. [pmid: 7130580].
Kanter JW, Santiago-Rivera AL, Rusch LC, et al. Initial outcomes of a culturally adapted behavioral activation for Latinas diagnosed with depression at a community clinic. Behav Modif. 2010;34(2):120-44. [pmid: 20176914].
Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. 2004;61(10):1042-9. [pmid: 15466678].
Konnert C, Dobson K, Stelmach L. The prevention of depression in nursing home residents: a randomized clinical trial of cognitive-behavioral therapy. Aging Ment Health. 2009;13(2):288-99. [pmid: 19347696].
Kotova E. A meta-analysis of Interpersonal Psychotherapy. ProQuest Information & Learning. 2005.
LaPointe K, Rimm D. Cognitive, assertive, and insight-oriented group therapies in the treatment of reactive depression in women. Psychotherapy: Theory, Research and Practice. 1980;17:312-321.
Latour D, Cappeliez P. Pretherapy training for group cognitive therapy with depressed older adults. Canadian Journal on Aging. 1994;13(2):221-235.
Lichtenberg P. Behavioral Treatment of Depression in Predominantly African-American Medical Patients. Clin Gerontol. 1996;17(2):15-33.
Lynch D, Laws KR, McKenna PJ. Cognitive behavioural therapy for major psychiatric disorder: does it really work? A meta-analytical review of well-controlled trials. Psychol Med. 2010;40(1):9-24. [pmid: 19476688].
Mackin RS, Arean PA. Evidence-based psychotherapeutic interventions for geriatric depression. Psychiatr Clin North Am. 2005;28(4):805-20. vii. viii. [pmid: 16325730].
Mazzucchelli T, Kane R, Rees C. Behavioral activation treatments for depression in adults: A meta-analysis and review. Clinical Psychology: Science and Practice. 2009;16(4):383-411.
McCurren C, Dowe D, Rattle D, et al. Depression among nursing home elders: testing an intervention strategy. Appl Nurs Res. 1999;12(4):185-95. [pmid: 10589107].
McKnight D, Nelson-Gray R, Barnhill J. Dexametnasone test and response to cognitive therapy and antidepressant medication. Behavior Therapy. 1992;23(1):99-111.
McNaughton JL. Brief interventions for depression in primary care: a systematic review. Can Fam Physician. 2009;55(8):789-96. [pmid: 19675262].
Miranda J, Chung JY, Green BL, et al. Treating depression in predominantly low-income young minority women: a randomized controlled trial. JAMA. 2003;290(1):57-65. [pmid: 12837712].
Mohr DC, Vella L, Hart S, et al. The effect of telephone-administered psychotherapy on symptoms of depression and attrition: A meta-analysis. Clinical Psychology: Science and Practice. 2008;15(3):243-253. [pmid: 21369344].
Montgomery EC, Kunik ME, Wilson N, et al. Can paraprofessionals deliver cognitive-behavioral therapy to treat anxiety and depressive symptoms?. Bull Menninger Clin. 2010;74(1):45-62. [pmid: 20235623].
Mynors-Wallis L, Davies I, Gray A, et al. A randomised controlled trial and cost analysis of problem-solving treatment for emotional disorders given by community nurses in primary care. Br J Psychiatry. 1997;170:113-9. [pmid: 9093498].
Nezu AM, Nezu CM, Felgoise SH, et al. Project Genesis: assessing the efficacy of problem-solving therapy for distressed adult cancer patients. J Consult Clin Psychol. 2003;71(6):1036-48. [pmid: 14622079].
Nezu AM, Perri MG. Social problem-solving therapy for unipolar depression: an initial dismantling investigation. J Consult Clin Psychol. 1989;57(3):408-13. [pmid: 2738213].
Oranta O, Luutonen S, Salokangas RK, et al. The outcomes of interpersonal hristian on depressive symptoms and distress after myocardial infarction. Nord J Psychiatry. 2010;64(2):78-86. [pmid: 19919291].
Pace T, Dixon D. Changes in depressive self-schemata and depressive symptoms following cognitive therapy. Journal of Counseling Psychology. 1993;40(3):288-294.
Parker G, Fletcher K. Treating depression with the evidence-based psychotherapies: A critique of the evidence. Acta Psychiatr Scand. 2007;115(5):352-359. [pmid: 17430412].
Pecheur D, Edwards K. A comparison of secular and religious versions of cognitive therapy with depressed hristian college students. Journal of Psychology and Theology. 1984;12(1):45-54.
Peden AR, Hall LA, Rayens MK, et al. Reducing negative thinking and depressive symptoms in college women. J Nurs Scholarsh. 2000;32(2):145-51. [pmid: 10887713].
Peng XD, Huang CQ, Chen LJ, et al. Cognitive behavioural therapy and reminiscence techniques for the treatment of depression in the elderly: a systematic review. J Int Med Res. 2009;37(4):975-82. [pmid: 19761679].
Petersen T, Pava J, Burchin J, et al. The role of cognitive-behavioral therapy and fluoxetine in prevention of recurrence of major depressive disorder. Cognit Ther Res. 2010;34:13-23.
Pigeon WR, May PE, Perlis ML, et al. The effect of interpersonal psychotherapy for depression on insomnia symptoms in a cohort of women with sexual abuse histories. J Trauma Stress. 2009;22(6):634-8. [pmid: 19885874].
Powers MB, Zum Vörde Sive Vörding MB, Emmelkamp PMG. Acceptance and commitment therapy: A meta-analytic review. Psychother Psychosom. 2009;78(2):73-80. [pmid: 19142046].
Reynolds CF 3rd, Miller MD, Pasternak RE, et al. Treatment of bereavement-related major depressive episodes in later life: a controlled study of acute and continuation treatment with nortriptyline and interpersonal psychotherapy. Am J Psychiatry. 1999;156(2):202-8. [pmid: 9989555].
Sallis J, Lichstein K, Clarkson A, et al. Anxiety and depression management for the elderly. Stalgeitis, Sinternational Journal of Behavioral Geriatrics. 1983;1(4):3-12.
Serfaty MA, Haworth D, Blanchard M, et al. Clinical effectiveness of individual cognitive behavioral therapy for depressed older people in primary care: a randomized controlled trial. Arch Gen Psychiatry. 2009;66(12):1332-40. [pmid: 19996038].
Shaw BF. Comparison of cognitive therapy and behavior therapy in the treatment of depression. J Consult Clin Psychol. 1977;45(4):543-51. [pmid: 886034].
Sirey JA, Bruce ML, Alexopoulos GS. The Treatment Initiation Program: an intervention to improve depression outcomes in older adults. Am J Psychiatry. 2005;162(1):184-6. [pmid: 15625220].
Stulz N, Thase ME, Klein DN, et al. Differential effects of treatments for chronic depression: a latent growth model reanalysis. J Consult Clin Psychol. 2010;78(3):409-19. [pmid: 20515216].
Taylor F, Marshall W. Experimental analysis of a cognitive-behavioral therapy for depression. Cognit Ther Res. 1977;1(1):59-72.
Thompson L. Efficacy of psychotherapy in the treatment of Advances in behavior research and therapy. 1984;6(2):127-139.
Thompson L, Gallagher D, Breckenridge J. Comparative effectiveness of psychotherapy for depressed elders. Journal of Consulting and Clinical Pyshcology. 1987;55(3):385-390.
Tsang HW, Chan EP, Cheung WM. Effects of mindful and non-mindful exercises on people with depression: a systematic review. Br J Clin Psychol. 2008;47(Pt 3):303-22. [pmid: 18237457].
Uebelacker LA, Weisberg RB, Haggarty R, et al. Adapted behavior therapy for persistently depressed primary care patients: an open trial. Behav Modif. 2009;33(3):374-95. [pmid: 19282506].
Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. 2002;288(22):2836-45. [pmid: 12472325].
van Calker D, Zobel I, Dykierek P, et al. Time course of response to antidepressants: predictive value of early improvement and effect of additional psychotherapy. J Affect Disord. 2009;114(1-3):243-53. [pmid: 18849079].
Warmerdam L, van Straten A, Jongsma J, et al. Online cognitive behavioral therapy and problem-solving therapy for depressive symptoms: Exploring mechanisms of change. J Behav Ther Exp Psychiatry. 2010;41(1):64-70. [pmid: 19913781].
Watkins ER, Baeyens CB, Read R. Concreteness training reduces dysphoria: proof-of-principle for repeated cognitive bias modification in depression. J Abnorm Psychol. 2009;118(1):55-64. [pmid: 19222314].
Watkins ER, Moberly NJ. Concreteness training reduces dysphoria: a pilot proof-of-principle study. Behav Res Ther. 2009;47(1):48-53. [pmid: 19036353].
Wierzbicki M, Bartlett T. The efficacy of group and individual cognitive therapy for mild depression. Cognit Ther Res. 1987;11(3):337-342.
Wood BC, Mynors-Wallis LM. Problem-solving therapy in palliative care. Palliat Med. 1997;11(1):49-54. [pmid: 9068685].
Yang TT, Hsiao FH, Wang KC, et al. The effect of psychotherapy added to pharmacotherapy on cortisol responses in outpatients with major depressive disorder. J Nerv Ment Dis. 2009;197(6):401-6. [pmid: 19525739].
Zerhusen JD, Boyle K, Wilson W. Out of the darkness: group cognitive therapy for depressed elderly. J Psychosoc Nurs Ment Health Serv. 1991;29(9):16-21. [pmid: 1941727].