# REVIEWER COMMENTS AND RESPONSES

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | No – I can't follow the literature review here or in the text. KQ 1 involves evaluation of “brief therapies” which seem to be defined as 8 or fewer sessions. | We have added further explanation to both the Methods and Results sections of our overall approach and more explanation of what constitutes a “complex systematic review.” We have also clearly delineated that, for the purposes of this review, ≤ 8 sessions are defined as “brief,” 12 to 20 sessions are described as “standard,” and psychotherapies of other durations are specifically designated.
1 | In general, I just don't get the Results for KQ1. I wonder if organizing your results by type of therapy might be more helpful. For example, “We identified X articles evaluating CBT: X were from the primary literature review and X were identified from the systematic reviews. | We have further clarified our overall approach and portions of KQ 1 to make apparent our structure of discussing systematic review findings prior to primary literature findings.
1 | Results: I have read this 3 times and still cannot follow the flow of literature. This needs to be clarified. Figure 2 also could be clarified by adding 2 boxes below the one describing the 2 SR's which shows how many articles come from each of the SR's and then connecting it to the very bottom box. | We have altered the literature flow figure to better indicate how we used the primary literature and systematic reviews.
1 | Nice summary and discussion. | Thank you.
1 | I think the important point that most of these studies involve women deserves more than a line in the limitations section. This is a huge issue for the VA. Were you able to tease out any gender sub-analyses from the SR's or the original articles? | We agree and have added consideration of this point to the discussion section. While we agree that a subanalysis would be interesting, we have not conducted such an analysis because the data are not adequate or appropriate, and AHRQ guidelines recommend against such analyses.
2 | Unsure – Overall, the objectives, scope, and methods are clearly described. However, it is recommended that additional specificity be provided in references to “brief” versus “longer duration” psychotherapies throughout the manuscript, including the executive summary (e.g., p. 1, lines 14-15: “First, brief psychotherapies compared to longer duration psychotherapies had similar effect sizes.”) The reference “longer duration” is often used in the report to refer to psychotherapy lengths that are still quite brief (e.g., 7-8+ sessions). Because this term is typically associated with psychotherapies of longer lengths (e.g,, 12-16+ sessions), it would likely be helpful to be specific in such references to avoid confusion. Furthermore, there was a finding of a larger effect for the somewhat longer duration EBPs, though overlapping confidence intervals led to the conclusion that the evidence was inadequate to make a definitive determination. Thus, it is somewhat unclear what led to the statement above of similar effect sizes for brief vs. “longer” duration psychotherapies. | We have now clearly delineated that, for the purposes of this review, ≤ 8 sessions are defined as “brief,” 12 to 20 sessions are described as “standard,” and psychotherapies of other durations are specifically designated. We have also clarified our interpretation of overlapping confidence intervals for “brief” versus “standard” length psychotherapy.
3 | Yes – No comment. | Acknowledged
4 | Yes – The rationale for focusing the review on brief (8 or fewer sessions) is clear. The methodology employed in the review is well described. It was somewhat surprising that there was not a key question included that focused on a comparison of brief versus slightly longer standard psychotherapy (e.g., 12 to 16 sessions) in primary care. The authors note on Page 1, line 10 that there are guidelines recommending 12 to 16 one-hour sessions. For this reviewer, this number of sessions is the usual “gold standard” for clinical treatment and for clinical research in this area. Thus it would have been helpful to have a sense whether there is evidence that briefer treatment (8 or fewer sessions) is as efficacious as longer treatment. | The review that we originally proposed to conduct would have made this comparison. However, a variety of reasons contributed to our VA stakeholders recommending against conducting this comparison. Fortunately, the Cuijpers' systematic review addresses this comparison and allows us to make some tentative conclusions about comparative efficacy.
5 | Yes – The objectives and scope are very clearly described and this review adheres nicely to its objectives and scope. The description of the search strategy (page 14) was somewhat confusing, particularly with regards to the selection of the specific dates to include in the Jan 2009-Aug 2010 search of MEDLINE, PsycINFO, Embase. After reading it a few times, I think I understand why those dates were chosen, but am still not entirely confident. | We have reworked this section to provide clarification on our search strategy.
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | Not answered but no comments. | Acknowledged
2 | No – no comment. | Acknowledged
3 | No – no comment. | Acknowledged
4 | No – This appears to be an exhaustive search of the literature, and the synthesis of the available data is excellent. | Thank you.
5 | No – no comment. | Acknowledged
Question 3: Are there any studies of interest to the VA that we have overlooked?
1 | Not answered but also not addressed | Acknowledged
2 | No – no comment. | Acknowledged
3 | No – no comment. | Acknowledged
4 | No – None that this reviewer is aware of. | Acknowledged
5 | No – no comment. | Acknowledged
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | On page 5 lines 6 and 7. 15 articles are described. | We have clarified the number of articles being described.
1 | Next, on page 5 line 16 is a description of findings from the systematic reviews of 6-16 sessions but I thought the focus was on brief interventions? | The reference to 6-16 sessions has been deleted so that the focus of this section of the Executive Summary is exclusively on brief psychotherapies.
1 | Line 21 then talks about a meta-analysis of 6 trials. Where did 6 come from? | This sentence was reworded to indicate that the 6 trials were a subset of CBT trials that we examined.
1 | Line 8 page 6—What about the other systematic review? Any data on number of sessions from it? | The other systematic review was limited exclusively to brief psychotherapies, so no comparison could be made between brief psychotherapies and standard-length psychotherapies.
1 | Page 8, lines 2 and 3 contain information that should be presented earlier in the Results section (perhaps page 5 first paragraph). This limitation should still be discussed in the conclusions. | This information is now also presented early in the Results section of the Executive Summary.
1 | Methods: Page 14 lines 9 on—This paragraph needs to be clearer and for clarity, each search strategy should probably have its own paragraph. I believe lines 11-14 belong in the Results section. | Separate paragraphs have been created to enhance clarity, and the referenced lines have been moved to appropriate places in the Results section.
1 | Methods: Data Synthesis—Clarify what you mean in line 20 page 17. Which findings are you summarizing—the unique studies or the reviews findings? | We have clarified that we summarize in narrative form the systematic review findings.
1 | On page 22 line 5 the 2 systematic reviews are described and the authors identify 7 articles that are relevant to the review. Next, on page 24 line 1, the authors describe a systematic review including 34 studies but imply, not clearly however, that 14 of them contribute to the KQ addressed in this review. How did you get from 34 articles to the 9 articles described on page 23 and in Figure 2? How many came from the Cape review? The entire paragraph describing the Cape review needs to be clarified. | The reason for this discrepancy is that the Cuijpers review was described on page 22, while the Cape review was described on page 24. We have made changes throughout the document to more fully describe the “complex systematic review” that we conducted, including why we report on reviews that cover some articles that did not meet our inclusion criteria for individual studies (i.e., a systematic review could meet our inclusion criteria for systematic reviews even if not every article covered in a review met our inclusion criteria for primary literature).
1 | Page 25. Lines 3-6 are already in Methods. | This section has been modified to parallel our description results for the systematic review search.
1 | Lines 9-12 on page 25 are helpful. | Acknowledged
1 | Page 29 line 1. It would be helpful to begin, “Of the 15 unique studies, six studies…” so that it is clear where you are going with this paragraph. | Change made as suggested.
1 | Page 29 line 11—I would begin a new paragraph with, “The intervention…” | Change made as suggested.
1 | Page 30 line 17—Why 15 RCT's? I though you only found 8? Help! Why are you reporting the findings from their review when it does not address KQ1 dealing with brief therapies? This is confusing! | Please see above response for how we clarified this apparent discrepancy.
1 | Page 31 line 7—34 studies? You just talked for a few pages about how you got to 15. Clarify. | Please see above response for how we clarified this apparent discrepancy.
1 | Page 32—lines 3-9 need to be clarified. Perhaps using subtitles such as CBT or MBCT would be helpful? | We have altered the position of CBT in the initial sentence to help clarify that this paragraph is exclusively about CBT.
1 | Page 36 line 20—? 9 sessions? | We have changed “fewer than 9” to “≤ 8.”
1 | If you have data on medical therapy among the controls in the 15 studies this would be very helpful. Were most of the controls treated with medicine or just followed? Since this is the comparison most people are interested in, it seems to me that it deserves more discussion | For the purposes of this review, we intentionally excluded trials that used standardized medication protocols (i.e., what we considered a separate active treatment condition). Many of the control groups were “usual care,” which could possibly entail patients receiving medication, but usual care was highly variable.
2 | The conclusion that brief EBPs are efficacious is somewhat tenuous, given the limited state of the research in this area and the limitations of many of the studies (e.g., many low quality studies, high heterogeneity, limited definition of usual care comparison groups, small effect sizes), methodology required for the review (pooled comparisons), and significant differences between the samples included in the reviewed studies and the Veteran population. While the report notes many of these limitations, it is recommended that the conclusion in the Discussion (p. 40, lines 2-3; “We conclude that brief psychotherapy is an efficacious treatment option for patients with depression in VA primary care settings”) be qualified somewhat. Further, in the Cuijpers review, the finding of a significant effect for brief EBPs was only seen for studies in which patients were referred by their GP for treatment but not for those recruited through systematic screening. Given the magnitude of the differential effect, it may be worth noting this more directly in response to Question 1 in the Discussion. Moreover, while it may very well be that brief EBP is an efficacious treatment option for VA primary care settings, the reviewed studies were conducted overwhelmingly on non-Veterans. Perhaps more significant, many of the studies had diagnoses commonly seen in Veteran primary care patients as exclusionary criteria (e.g., substance abuse, psychosis, suicidality). This is worth explicitly noting in the context of discussing and perhaps qualifying the conclusions somewhat. There is brief, one-sentence mention in the Limitations section that the studies in the review was composed primarily middle-aged, Caucasian females, which does not seem sufficient. | We concur with many of these points and have qualified the statement. We have now commented on the differential effect between GP referral and systematic screening in the Discussion of KQ 1. We have more overtly acknowledged the limitations for the Veteran population, including the low representation of Veterans in the studies we reviewed, lack of comorbidity, and overrepresentation by middle-aged Caucasian females.
2 | It seems difficult to make highly meaningful interpretations of the results of many of the treatment group comparisons (e.g., brief EBP vs. usual care), since usual care was poorly described and variable in the reviewed studies. Furthermore, it is safe to assume that care as usual in many of most of the reviewed studies did not consist of evidence-based “care management,” as is now implemented in most VA primary care settings. It would likely be valuable to note this in the Discussion. | We have commented on the VA's commitment to evidence-based care management in the Discussion. To our knowledge, the data remain out on whether VA's investment in evidence-based care management has in practice resulted in significantly better usual care than was received in the studies we reviewed.
2 | Given the lack of research comparing brief EBPs with full course EBPs, it is important that the implementation of brief EBPs not come at the expense or replacement of full course EBPs (which could occur due to local leadership perception that brief EBPs are effective and a desire for efficiency). The report notes that a comparison of brief EBPs with full course EBPs was not directly tested in the studies included in the review and suggests this, appropriately so, as an area of future inquiry. While direct comparison of brief vs. full course EBPs was not tested in the studies included in the review, it might be valuable to note the effect sizes commonly found in reviews of full course CBT and PST, or to consider this separately. | We sympathize with these concerns. After careful consideration, we have decided not to cite effect sizes for evidence-based psychotherapies from other reviews, as these effect sizes could be misleading should the reader compare them to the effect sizes we report for brief psychotherapy. Fortunately, the Cuijpers review makes this comparison in a subset of carefully selected trials, and we have elaborated on the caution warranted in interpreting their comparison because it is indirect and large Cis are involved.
2 | P. 40, lines 11-12: There does not seem to be sufficient evidence to support the conclusion that “broad training in mental health may not be necessary to provide these therapies.” It is noted in the manuscript that some of the studies included therapists who were “graduate students, nurses, general practitioners, and other allied health professionals.” It is further suggested that “Within the VA, a range of providers could be considered, including nurses, nurse practitioners, primary care physicians, social workers, and chaplains” to deliver brief EBPs. However, the inclusion of some non-MH providers in some studies does not seem sufficient for determining that individuals without background in mental health could deliver these treatments effectively (or as effectively) as mental health professionals, and there is no data to indicate the extent to which mental health training had an impact on, or moderated, outcomes. In fact, because the results were pooled across different provider types, it is quite possible that effects would have been higher if the treatments were delivered by mental health providers. It is also possible that there was not a significant effect for CBT or PST when delivered by non-MH providers. Were results of the studies available by provider-type? In addition, GPs and others noted above were identified in some of the PST studies; were these provider-types also included for CBT? Furthermore, VA patients are typically more complex and often have comorbidities (substance abuse, suicidality, psychosis) that were excluded in many of the reviewed studies and would often require a higher level professional to monitor and sometimes adapt treatment for. In addition, several of provider-types noted above are not locally credentialed to deliver brief EBPs in VHA. It is also worth noting that graduate students and clinical social workers (as well as nurses with background in mental health) are considered mental health providers in VHA and often do deliver EBPs, along with psychologists and psychiatrists. | We have tempered our statements regarding necessary training and emphasized the need for more research on the use of “non–mental health professionals” to provide brief EBPs.
2 | EBPs have often been shown to more efficacious in treating major depression than dysthymia. It may be useful to break out results for different types of depression to the extent that this is possible (i.e., if there are sufficient number of studies/participants without mixed diagnostic groups). | We have now included in our KQ 1 Results information from the Cuijpers review on MDD versus “other” diagnoses.
2 | The finding of Cape of a large effect size for treatment of anxiety is interesting and significantly higher than the effect-sizes for mixed anxiety and depression and depression only. Although anxiety is beyond the scope of the current review, it would be interesting to know what type of anxiety this included (e.g., generalized anxiety or other specific forms of anxiety?). Might this finding be an artifact of the research (e.g., smaller sample size), rather than the being a true differential effect for this condition? | We now note that “anxiety” refers predominantly to diagnoses of panic and generalized anxiety disorder. Although we do not expound on this finding because it is beyond the scope of this review, we would caution interpretation of the difference due to the indirect comparison methodology, but we would also suggest that the finding may represent a true difference and is of value as a hypothesis generating finding.
3 | This is a well done review. Methods used to identify studies were appropriate. Decision to review previously published reviews and add additional studies not included in those reviews seems a good one. Tables 3 and 4 do a nice job of summarizing the included studies – they are well organized and easy to understand. | Thank you.
3 | The moderate effect size in relation to usual care was noted. I wonder if an analysis could be done to see if there is an association between depression severity and effect size. I would hypothesize that psychotherapy would be most effective for those with moderate symptoms, less effective for those with mild symptoms, and least effective (at least as monotherapy) for those with severe symptoms. It would be useful to know if the literature supports targeting any subgroups of patients as the best candidates for brief psychotherapy. | Such an analysis was not possible with the data obtained from the primary literature. However, we have added as a limitation our inability to answer this question.
4 | Given the large numbers of older veterans receiving care in the VA system, some mention of acceptability and efficacy of brief psychotherapies in older adults would help the discussion. Several of their cited studies include or are entirely focused on older adults, so some specific comment on this population would help. This is particularly relevant since older white males have among the highest rates of completed suicide, and studies have shown that a large proportion of completed suicide victims in this age group have recently seen a primary care physician. In sum, the inclusion of a discussion of the relevance of depression in older veterans would add much to the report. | The 2 out of 15 studies that contained elderly participant samples are now separately examined in the Results. Also, additional mention on lack of data in Veteran samples (or male/elderly samples) is now made in the Discussion.
5 | This is a very clearly written report that does a nice job utilizing the available research literature to address the key questions it sets out to answer. The ability of this review to identify and outline some shortcomings in our current knowledge base will provide an important foundation for future research on brief psychotherapies for depression and the use of psychotherapy in primary care settings. A study characteristic that is not addressed in this review, but may be useful to consider, or at least mention, is treatment dropout rate. | Thank you. We have revised a column heading in Table 4 to “Therapy completed” to indicate the number patients retained in the treatment condition (i.e., those that did not dropout).
5 | The remainder of my comments consist of minor wording suggestions or clarifications: Throughout the document, the word “Veteran” should be consistently capitalized. I would also suggest consistency in whether quality of life has hyphens between the words (i.e. quality-of-life) or not (i.e. quality of life). | “Veteran” and “Veterans” have been capitalized throughout. The phrase “quality of life” appears with hyphens when used as a unit modifier, as in “quality-of-life measures.” Most instances in the report are not this usage, so we have left those without hyphens.
5 | P 7, line 17 and p 40, line 11: the suggestion that “broad” training in mental health may not be necessary. I would guess that all of the other non-mental health specialists being discussed here probably do in fact have “broad” training in mental health, but may not have “extensive” or “specialized” training in mental health, so there may be a more accurate way to capture what you are trying to say here. | We have tempered our statements to more strictly state what we found in the review and to emphasize the need for more research on the use of “non–mental health professionals” to provide brief EBPs.
5 | Page 11, line 7 – suggest using “intensive” rather than “demanding” | Changed as suggested.
5 | Page 11, lines 14-17 – the wording of this sentence is awkward and therefore does not convey the importance of this review as clearly and strongly as possible. | The sentence has been split into two sentences and reworded.
5 | Page 21 and 22 – in the description of the Cuijpers review, p21, line 17 refers to 15 studies, but p 22, line 5 says, “Of the 16 trials…” | 16 was a mistake; we have changed to 15.
5 | Page 24, lines 13-14 – the sentence about what countries the studies were conducted in is confusing. Throughout most of this paragraph the authors are talking about the “14 depression studies” but then say that only one in seven were conducted in the US. Does this mean 2 of the 14 were conducted in the US? | Yes, that is what was meant. We have reworded the sentence to enhance clarity.
5 | Table 3: Does “most distal follow up” time period refer to the length of time between baseline and most distal follow up or between the end of treatment and the most distal follow up? It would be helpful to clarify this in the table (even if it is described in the text). | A footnote has been added to the table for clarification.
5 | Table 4: I would suggest moving the sample size to Table 3, since it seems more like a characteristic of the study than of the intervention. I would also suggest using “intervention n” or “treatment n” (and then define what this means) for that column rather than “completed n” and “control n”. It would make sense to keep the completion rates for the intervention arm as a column in Table 4. The therapy intensity column of Table 4 is a little difficult to digest. Perhaps having separate columns for session length and frequency of sessions would make it easier to understand? | We have split the therapy intensity column into two columns as suggested and have changed the column heading for “completed n.” We concur with the reviewer's sentiment that sample size is more a characteristic of the study than the intervention, but we decided not to move this information in order to consolidate information in Table 4 and to cut down on clutter in Table 3.
5 | Page 29, lines 17-18 – I would suggest re-wording this sentence to something like, “Follow-up duration was less than 6 months for 7 studies 6 months or greater for 8 studies.” | Sentence has been reworded as suggested.
5 | Page 29, line 21 refers to the fact that only 2 study samples included any Veteran representation. It might be helpful to add a little more detail about what proportion of the samples were Veterans in those 2 studies, or if they were studies specifically of Veterans, etc. | Additional detail has been added here and throughout the report.
5 | In the Cuijpers review, was the ES for ≤ 6 sessions smaller than it was for interventions that included more than 6 sessions? Page 31, line 3, reports that brief psychotherapies had a small but significant positive effect for treatment of depression in primary care – did Cuijpers examine whether this ES of -0.25 was statistically smaller than that for the full range of studies they looked at (ES -0.31 reported on page 30, line 19)? | The Cuijpers review does make a comparison between ≤ 6 sessions and > 6 sessions, and they did not find a statistically significant difference. We report these findings in KQ 2 because the comparison between brief and standard-duration psychotherapies is the focus of KQ 2.
5 | In the Cape meta analysis, is the ES of -0.21 reported on page 31, line 11 referring to the combined ES for depression AND mixed anxiety and depression? | Yes. We have clarified by identifying the different diagnostic categories from the outset of this paragraph and by pointing out that the authors combined diagnostic categories for some of their analyses.
5 | Page 31, lines 16-18 – The sentences describing the ES for brief psychotherapies specifically for depression is somewhat contradictory. On the one hand, the authors report a “slightly smaller” effect for PST over usual GP care (as compared to the effect for CBT over usual GP care), but then report “no significant differences in efficacy between CBT and PST. This could possibly be re-worded to say that the ES was slightly smaller, but not significantly different, for PST, but even this is still somewhat contradictory. (i.e. if it's not statistically significantly smaller, can it be called smaller?) | The issue here is that at the p = 0.05 level, CBT demonstrated statistical significance and PST did not. Because there was no statistically significant difference between CBT and PST, because CBT narrowly demonstrated statistical significance at the p = 0.05 level, and because PST would demonstrate statistical significance at a slightly more lenient p level (e.g., p = 0.06 or 0.07), we feel that it would be misleading to draw too much attention to the fact that CBT achieved significance (narrowly) at the arbitrary 0.05 mark and PST did not (narrowly). We have reworded this sentence to remove the contradiction.
5 | Page 32, line 11: I would suggest replacing “judged to” with “rated as” | Changed as suggested.
5 | Page 32, line 14: Do you want to add (n=1) after the word antidepressant? | Yes, changed as suggested.
5 | Page 33, line 9: I am unsure of exactly what the term “irregular comparator condition” means. | We have clarified this sentence by replacing the term “irregular comparator” with a more accurate description of the control condition.
5 | Figure 3: In the labels under the Sd diff in means and 95% CI, do the authors intentionally use “Favours” in stead of “Favors”? | The British spelling has been changed to “Favors.”
5 | Page 35, lines 12-14: Stating that “These results are consistent with both Cape's and Cuijpers' conclusion that PST is an efficacious option for the treatment of depression.” may be slightly overstating it, since one of the 2 studies did find a difference and the other did not, especially since the better quality trial did not find that PST improved outcomes. | We have altered a sentence to clarify that although the Mynors-Wallis study found PST+Med no better than Med alone, they also found that PST alone was equally as effective as Med alone. On this basis, we still conclude that the results are consistent with the conclusion that PST is an efficacious treatment option.
5 | Page 37, lines 10-13: The authors could put the number of studies with each type of provider in parentheses (e.g. n=3), as they did on page 32 (lines 11-14) | We retained the sentence structure to avoid ambiguity (e.g., n = 3 could be interpreted as 3 studies or as 3 psychologists).
5 | On page 38, I would suggest adding a sentence after line 3 noting that the numbers of studies in each subgroup were too small to conduct quantitative analyses of provider type, individual vs. group, telephone vs. in person or treatment intensity. Though this is fairly obvious, it would make it explicit and also make it consistent with other sections of the review in which similar decisions were made. | Changed as suggested.
5 | On page 40, line 1-2, I would suggest saying more about the statement, “However, usual care may represent a more potent control condition than placebo controls used in antidepressant trials.” What do the authors mean? What makes them think this could be the case? | We have expounded on this statement to describe that it may be the case that usual care is more effective than placebo control because patients treated with usual care are receiving what is intended to be an active treatment and could even be a “best practice” treatment.
5 | Page 40, line 14 – I would suggest changing the phrase “appropriate training and supervision” to something like “training and supervision specific to the intervention being conducted”. Since many studies do not give much detail about the training provided, and since we really don't have data that tells us how much or what kind of training is needed to implement these interventions, I'm not sure it can be deemed “appropriate” (or inappropriate) based on the information provided in each study. | Changed as suggested. We have also tempered our statements to more strictly state what we found in the review and to emphasize the need for more research on the use of “non–mental health professionals” to provide brief EBPs.
5 | Page 41, line 16 – suggest using the term “screened” rather than “selected” in reference to identifying patients who would be appropriate for brief psychotherapy | Changed as suggested.
5 | Page 42, line 11 – I would suggest replacing “appropriate” (in reference to the quantitative synthesis methods) with something like “rigorous” or “robust” to convey that you not only chose analyses that were appropriate, but that you chose the best available methods. This is indeed a strength of this review and even that slight wording change conveys that in a stronger manner. | Changed as suggested.