# EVIDENCE TABLES

## BRIEF PSYCHOTHERAPY FOR DEPRESSION IN PRIMARY CARE

Study ID: Barnhofer, Crane, Hargus, et al., 2009

Study Information | Participants | Interventions | Results and Adverse Effects | Comments/Quality Scoring
Geographical location: Oxford, England Recruitment method:; - Advertisement; - Referral; Recruitment setting:; - Mental health; - Nonclinical; Treatment setting:; - Mental health; - Academic; Study design: RCT Number of participants enrolled: 31 Duration of followup: 8 wk | Age: Mean (SD): 42 MBCT: 42.07 (11.34) TAU: 41.79 (9.52) Median: NR Range: 18 to 65 Education: Mean (SD) MBCT: 16.38 (3.04) TAU: 15.21 (3.19) Sex: Female n (%): 19 of 28 (68%) MBCT: 10 of 14 (71%) TAU: 9 of 14 (64%) Race/ethnicity: NR Veterans: NR Baseline depression assessment(s): Criterion: DSM-IV Disorder: Chronic MDD n (%) MBCT: 7 (50%) TAU: 12 (85%) Current: 100% Severity score: mean (SD) MBCT: 29.36 (9.66) TAU: 31.32 (10.79) Chronicity: 20+ years for current Prior episodes: At least 3 prior episodes lasting 2 yr Comorbid psychiatric conditions: N (%) Alcohol/substance abuse: Excluded Anxiety disorder: MBCT: 4 (28%) TAU: 6 (42%) PTSD: NR Other: Suicide attempt: 8 (56%) MBCT: 4 (28%) TAU: 4 (28%) Comorbid chronic medical conditions: NR Inclusion criteria:; 1. History of 3 episodes MDD; 2. Current MDD or subthreshold MDD; 3. History of suicidality; 4. Absence of other severe mental health diagnosis, especially self-harm; 5. Adequate written and oral English; 6. Not currently in treatment; 7. Ages 18 to 65; Exclusion criteria: NR | Intervention description: RCT of 2 arms:; 1. MBCT: 14 participants; 2. TAU: 14 participants; Depression intervention(s): [underlined: Behavioral intervention] Type: MBCT for 8 sessions of 2-hr duration delivered via manual (Segal, 2002) modified for suicidality with homework of mindfulness practice 1 hr per day, 6 days per wk Delivery: Group Intensity: 8 weekly 2 hr Fidelity monitoring: Yes Other notes about intervention: All on some type of antidepressant [underlined: Therapist] Discipline: CBT Experience: NR Training: internship at the Center for Mindfulness in Medicine, University of Massachusetts Comparator: [underlined: Behavioral control] Type: TAU Delivery: Mixed Intensity: Mixed Fidelity monitoring: No Other notes about control: All on some type of antidepressant Cointervention—psychotropic drugs: None | Eligible randomized: 31 of 34 (91%) Followup rate: Total: 28 of 31 (90%) MCBT: 14 of 16 (86%) TAU: 15 of 16 (94%) Important baseline differences: Presence of chronic depression higher in TAU (n = 12) versus MBCT (n = 7), p = 0.04 Depression outcomes: BDI-II Response rates n (%): BDI fell to < 13 MBCT: 6 (37) TAU: 1 (6) P = 0.04 Change in diagnosis: MBCT: 7 of 10 TAU: 2 of 11 P = 0.03 Severity score: mean (SD) MBCT: 17.62 (10.94) TAU: 28.86 (12.97) HRQOL outcomes: NR Other outcomes: Social: No Occupational: No Satisfaction: No Suicidal ideation: Yes Treatment discontinuation rate: 3 (9.7%) Adverse effects: None reported related to intervention | General comments: Stats were LOCF – now frowned upon in favor of modeling or imputation Study-level quality assessment: Good Assessment of adverse effects adequate? Yes Applicability:; - High education; - Mostly women

Study ID: Laidlaw, Davidson, Toner, et al., 2008

Study Information | Participants | Interventions | Results and Adverse Effects | | | | Comments/Quality Scoring
Geographical location: UK (Fife and Glasgow) Recruitment method: Referral Recruitment setting: Primary care Treatment setting:; - Unclear; - Nonacademic; Study design: RCT Number of participants enrolled: 44 Duration of followup: 6 mo | Age: Mean (SD) CBT: 74 (8.39) TAU: 74.05 (7.62) Median: NR Range: NR Education: Mean (SD) CBT: 10.10 (1.74) TAU: 9.9 (1.29) Sex: Female n (%): CBT: 11 (60%) TAU: 18 (85%) Race/ethnicity: NR Veterans: NR Baseline depression assessment(s): BDI ns CBT: 19.6 (5.22) TAU: 19.5 (5.48) GDS ns CBT: 7.6 (2.7) TAU: 8.5 (3.55) HAM-D ns CBT: 11.4 (3.08) TAU: 11.8 (2.84) Disorder: MDD Severity: NR Chronicity: NR Prior episodes: NR Comorbid psychiatric conditions: N (%) Alcohol/substance abuse: NR PTSD: NR Other anxiety disorder: NR Other: Axis I disorder: CBT-2 (10%), 6 (30%) Comorbid chronic medical conditions: Mean (SD) CBT: 2.26 (1.2) TAU: 2.2 (0.83) Conditions not specified Inclusion criteria:; 1. Age 60 or over; 2. Met DSM-IV criteria for MDD using the SADS-L structured interview; 3. HAM-D = 7-24; 4. BDI-II = 13 to 28; 5. Can provide written consent; 6. Not prescribed antidepression medication within 3 mo of referral to trial; Exclusion criteria:; 1. Insufficient knowledge of English; 2. MMSE < 22; 3. Received more than 6 sessions of CBT in the past or currently receiving psychological therapy | Intervention description: Two arms:; 1. CBT: 21 participants; 2. TAU: 23 participants; CBT followed conceptual model and protocol developed by Beck. TAU was as close to standard care as possible. No restrictions on type of treatment; also, no treatment was allowed if GP thought appropriate. Depression intervention(s): [underlined: Behavioral intervention] Type: CBT Delivery: Mean 8 sessions (SD = 4.7, range 2 to 17) Intensity: NR (assumed weekly since adhering to Beck's protocol) Fidelity monitoring: Yes, audiotaped and rated with Cognitive Therapy Rating Scale by cognitive therapy experts Other notes about intervention: Assumption is that the sessions were weekly given that they said they adhered to Beck's model, in which case post results should approximate 8 sessions; however, frequency of sessions not provided. [underlined: Therapist] Discipline: Psychology Experience: NR Training: Master's level (except for one who was graduate level with several years of experience) Comparator: [underlined: Behavioral control] Type: TAU Delivery: Standard care Intensity: At GP's discretion Fidelity monitoring: Yes, checking GP notes at the end of study and asking participants about treatment received; however, no adherence data since there were guidelines given to GPs Other notes about control: 16 (80%) received medications Cointervention—psychotropic drugs: Drug name/dose: None provided by the study Clinician discipline: NA | Eligible randomized: 61% (based on Figure 1, 115 referred, 28 + 44 eligible, 44 randomized) Followup rate: 40 (90.9%) Important baseline differences: Gender (TAU had higher percentage of female; CBT had higher percentage of male) Depression outcomes: Response rates: CBT: 20 TAU: 20 BDI | | | | General comments:; - Adequate randomization; - Missing data adequately addressed; - Blinding not possible given intervention but assessors were blinded; - No concerns regarding selective outcome reporting; - No conflicts of interest; Study-level quality assessment Fair Comments:; - Small sample size; - Missing information from the protocol that would allow evaluation of applicability to our question; Assessment of adverse effects adequate? Unclear Applicability: [underlined: To general population:] Yes [underlined: To Veterans:] Yes Limitations:; - Not enough information on disease severity; - Intensity of therapy not given; - UK primary care may differ from US
| | | | CBT | TAU | F, p
| | | Post treatment | 9.4 (8.56) | 13.25 (10.3) | 1.65 0.21
| | | 3 mo | 9 (8.16) | 12.9 (9.34) | 1.98 0.17
| | | 6 mo | 10.55 (9.05) | 15.10 (11.83) | 1.87 0.18
| | | GDS
| | | | CBT | TAU | F, p
| | | Post treatment | 3.85 (3.83) | 5.3 (3.48) | 1.57 0.22
| | | 3 mo | 5 (3.71) | 4.9 (3.35) | 0.008 0.93
| | | 6 mo | 5.05 (3.46) | 5.75 (3.72) | 0.38 0.54
| | | HAM-D
| | | | CBT | TAU | F, p
| | | Post treatment | 5.25 (4.48) | 7.75 (6.05) | 2.2 0.15
| | | 3 mo | 5.15 (4.75) | 6.7 (6.23) | .78 0.38
| | | 6 mo | 6.7 (5.03) | 7.55 (6.13) | .23 0.63
| | | HRQOL outcomes: WHOQOL Physical Subscale
| | | | CBT | TAU | F, p
| | | Post treatment | 22.4 (5.02) | 19.85 (4.34) | 0.29 0.59
| | | 3 mo | 21.6 (3.66) | 20.75 (5.3) | 0.02 0.9
| | | 6 mo | 21.35 (5.34) | 20 (5.69) | .0.75 0.39
| | | WHOQOL Psychological Subscale
| | | | CBT | TAU | F, p
| | | Post treatment | 20.65 (3.13) | 18.15 (3.66) | 0.14 0.71
| | | 3 mo | 19.65 (2.62) | 19.15 (3.13) | 0.08 0.78
| | | 6 mo | 19.2 (3.43) | 17.75 (3.99) | 2.39 0.13
| | | Other outcomes: Social: WHOQOL Social Relationships
| | | | CBT | TAU | F, p
| | | Post treatment | 10.05 (2.66) | 9.95 (1.4) | 1.72 0.09
| | | 3 mo | 11 (1.26) | 10.55 (1.23) | 0.35 0.56
| | | 6 mo | 10.5 (1.4) | 10.2 (1.47) | 0.77 0.44
| | | Occupational: NR Satisfaction: NR Treatment discontinuation rate: Withdrew from study at 6 mo followup: CBT: 2 TAU: 4 Adverse effects: NR

Study ID: Mynors-Wallis, Gath, Day, et al., 2000

Study Information | Participants | Interventions | Results and Adverse Effects | Comments/Quality Scoring
Geographical location: Oxfordshire, UK Recruitment method: Referral Recruitment setting: Primary care Treatment setting:; - Primary care (i.e., patients' home or local health center); - Nonacademic; Study design: RCT Number of participants enrolled: 71 Duration of followup: 52 wk | Age: Mean (SD) Med: 34 (NR) MedPST: 35 (NR) Median: NR Med range: 19 to 58 MedPST range: 19 to 62 Education: N (%) Med: 9 (25%) > 16 yr MedPST: 8 (23%) > 16 yr Sex: Female n (%) Med: 31 (86%) MedPST: 24 (69%) Race/ethnicity: White n (%) Med: 32 (89%) MedPST: 34 (97%) Veterans: No Baseline depression assessment(s): Criterion: HRSD ≥ 13 Disorder: 71 (100%) probable or definite MDD HRSD mean (95% CI) Med: 20.2 (19.1 to 21.4) MedPST: 19.8 (18.5 to 21.1) BDI mean (95% CI) Med: 30.2 (27.7 to 32.7) MedPST: 30.0 (27.3 to 32.6) CIS-D mean (95% CI) Med: 29.3 (27.3 to 31.2) MedPST: 29.0 (26.5 to 31.5) Chronicity: Med 12 (33%) > 6 mo MedPST: 13 (37%) > 6mo Prior episodes: Med ≥ 1: 19(53%) MedPST ≥ 1: 19(54%) Comorbid psychiatric conditions: Alcohol/substance abuse: NR (excluded) PTSD: NR (excluded) Other anxiety disorder: NR (excluded) Comorbid chronic medical conditions: NR Inclusion criteria:; 1. GP suspected MDD; 2. Probable or definite MDD on research diagnostic criteria; 3. HRSD ≥ 13; 4. MDD duration ≥ 4 wk; Exclusion criteria:; 1. Psychiatric disorder preceding MDD onset; 2. Concurrent MDD treatment; 3. Brain damage; 4. Learning difficulties; 5. Schizophrenia; 6. Drug dependence; 7. Recent alcohol abuse; 8. Physical illness; 9. MDD with psychotic features or suicidal intent | Intervention description: Four arms:; 1. Problem-solving treatment (PST) alone provided by GP (excluded from this analysis): 39 participants; 2. PST alone provided by nurse (excluded from this analysis): 41 participants; 3. Medication alone (Med): 36 participants; 4. Medication + PST (MedPST) provided by nurse: 35 participants; Depression intervention(s): [underlined: Behavioral intervention] Type: MedPST; PST for use in primary care settings was added to GP prescription of fluvoxamine or paroxetine Delivery: Individual Intensity: 6 sessions (first session, 1 hr; rest 30 min) over 12 wk Fidelity monitoring: No [underlined: Therapist] Discipline: Research practice nurse Experience: Participated in previous study as problem-solving therapist Training: Nursing; trained in PST by study investigator Comparator: [underlined: Behavioral control] Type: Med; GP prescribed fluvoxamine or paroxetine in accordance with practice guidelines Delivery: Individual Intensity: NR Fidelity monitoring: No Cointervention—psychotropic drugs : Drug name/dose : Fluvoxamine/initial dose 100 mg ; or paroxetine/initial dose 20 mg Clinician discipline : GP | Eligible randomized: 83% Followup rate: N (%) Med 6 wk: 34 of 36 (94%) MedPST 6 wk: 34 of 35 (97%) Med 12 wk: 34 of 36 (94%) MedPST 12 wk: 31 of 35 (89%) Med 52 wk: 30 of 36 (83%) MedPST 52 wk: 30 of 35 (86%) Important baseline differences: None Depression outcomes: HRSD Recovered (HRSD ≤ 7): Med 12 wk: 24 (67%) MedPST 12 wk: 21 (60%) Med 52 wk: 20 (56%) MedPST 52 wk: 23 (66%) Severity score mean (95% CI): Med 12 wk: 6.2 (3.7 to 8.6) MedPST 12 wk: 7.5 (5.2 to 9.9) Med 52 wk: 7.2 (5.1 to 9.2) MedPST 52 wk: 5.7 (3.4 to 7.9) BDI mean (95% CI) Med 12 wk: 11.8 (7.8 to 15.8) MedPST 12 wk: 9.3 (6.6 to 12.0) Med 52 wk: 11.5 (6.9 to 16.2) MedPST 52 wk: 8.6 (5.3 to 11.9) CIS mean (95% CI) Med 12 wk: 9.8 (6.1 to 13.5) MedPST 12 wk: 9.6 (6.3 to 12.9) Med 52 wk: 11.5 (7.3 to 5.6) MedPST 52 wk: 9.7 (5.9 to 13.6) HRQOL outcomes: None Other outcomes: Social: Yes (social adjustment scale) Occupational: No Satisfaction: No Treatment discontinuation rate: Med: 6 (17%) MedPST: 6 (17%) Adverse effects: N (%) Med medication side effects: 2 (6%) MedPST medication side effects: 4 (11%) | General comments: PST alone (provided by either GP or nurse) found to be equally efficacious to medication alone, and addition of PST to medication did not result in significant benefit Study-level quality assessment Good Assessment of adverse effects adequate? Yes; research interviewers were blind Applicability: [underlined: To general population:]; - Comorbid conditions not reported; - Therapists likely more skilled than typical providers; - UK treatment settings different than typical US primary care; [underlined: To Veterans:]; - Patient sample predominantly female; - From UK; - Treatment often provided in home

Study ID: Nezu, 1986

Study Information | Participants | Interventions | Results and Adverse Effects | Comments/Quality Scoring
Geographical location: USA Recruitment method: Advertisement Recruitment setting: Nonclinical (ad) Treatment setting:; - Mental health; - Academic (university psychology clinic); Study design: RCT Number of participants enrolled: 21 Duration of followup:; - 8 wk for PST vs WLC; - 6 mo for PST vs PFT | Age: Mean (SD): 41.73 (12.81) Median: NR Range: NR Education: Mean (SD):15.96 (2.59) yr Sex: Female n (%) PST: 10 (83%) WLC: 7 (78%) Race/ethnicity: NR Veterans: No Baseline depression assessment(s): Criterion: Research Diagnostic Criteria Disorder: 21 (100%) MDD BDI PST: 23.91 (7.09) WLC: 20.67 (5.39) MMPI-D PST: 81.36 (8.12) WLC: 78.76 (7.05) Chronicity: NR Prior episodes: NR Comorbid psychiatric conditions: Alcohol/substance abuse: NR (exclusion criterion) PTSD: NR Other anxiety disorder: NR Other: NR Comorbid chronic medical conditions: NR Inclusion criteria:; 1. Responded to advertisement; 2. BDI ≥ 16; 3. Depressive episode ≥ 4 weeks; 4. Meet Research Diagnostic Criteria for MDD; 5. MMPI-D T score > 70; Exclusion criteria:; 1. Mental retardation; 2. Psychotic symptomatology; 3. Active substance use; 4. Organic brain syndrome; 5. Current MDD treatment | Intervention description: Three arms:; 1. Problem-focused therapy (PFT) (excluded from this analysis): 11 participants; 2. Problem-solving therapy (PST): 12 participants; 3. Waitlist control (WLC): 9 participants; Depression intervention(s): [underlined: Behavioral intervention] Type: PST based on D'Zurrila and Nezu's (1982) five-component model Delivery: Group Intensity: 8 weekly 1.5 to 2 hr sessions Fidelity monitoring: Partial (weekly supervision to ensure adherence to relevant treatment manuals) Other notes about behavioral intervention: Therapist allegiance very likely a confound for PST vs PFT but not for PST vs waitlist [underlined: Therapist] Discipline: Two psychology graduate students Experience: Average 4.5 years supervised psychotherapy experience Training: Prior training in group therapy and PST model; weekly supervision from author during treatment period Comparator: [underlined: Behavioral control] Type: WLC invited to receive treatment at the end of 8-wk program Delivery: NA Intensity: NA Fidelity monitoring: No Cointervention—psychotropic drugs: None | Eligible randomized: 78% Followup rate: N (%) PST 8 wk: 11 of 12 (92%) WLC 8 wk: 6 of 9 (67%) (3 excluded because entered therapy in interim) PST 6 mo: 10 of 12 (83%) Important baseline differences: None Depression outcomes: BDI PST 8 wk: 9.82 (4.71) WLC 8 wk: 21.00 (6.27) PST 6 mo: 9.50 (3.64) MMPI-D PST 8 wk: 54.27 (4.62) WLC 8 wk: 76.33 (4.89) PST 6 mo: 52.50 (6.89) HRQOL outcomes: None Other outcomes: Social: No Occupational: No Satisfaction: No Treatment discontinuation rate: PST: 1 (8%) Adverse effects: NR | General comments: Therapist allegiance to and experience in PST both very high Study-level quality assessment Fair Comments:; - 33% of WLC excluded from analysis because sought treatment; - Outcome assessors were not blind (although clinical interview not used as outcome measure); - Therapist allegiance to PST likely very high; Assessment of adverse effects adequate? No Applicability: [underlined: To general population:]; - Patients recruited through newspaper ads; - Therapist skill in and adherence to PST higher than typical clinician; - Intensive treatment for PC setting; [underlined: To Veterans:]; - Patient sample predominantly female; - Comorbid conditions not reported; - University psychology clinic setting

Study ID: Simon, Ludman, Tutty, et al., 2004, and Simon, Ludman, and Rutter, 2009

Study Information | Participants | Interventions | Results and Adverse Effects | Comments/Quality Scoring
Geographical location: Washington State and Northern Idaho, USA Recruitment method: Registry (Group Health Cooperative membership) Recruitment setting: Primary care Treatment setting: Primary care Study design: RCT Number of participants enrolled: 600 Duration of followup: 6 wk,12 wk, and 24 wk | Age: Mean (SD) Usual care: 44.0 (16.0) Care management (CM): 44.9 (15.3) Psychotherapy + CM: 44.7 (15.7) Median: NR Range: NR Education: College graduate: 39.3% Sex: Female: 74.33% Race/ethnicity: White: 80% Veterans: NR Baseline depression assessment: Criterion: Hopkins Symptom Checklist (SCL) Disorder: NR Severity: mean (SD) Usual Care: 1.55 (0.62) CM: 1.54 (0.61) Psychotherapy + CM: 1.52 (0.59) Chronicity: NR Prior episodes: NR Comorbid psychiatric conditions: NR Alcohol/substance abuse: NR Anxiety disorder: NR PTSD: NR Other: NR Comorbid chronic medical conditions: NR Inclusion criteria:; 1. Beginning antidepressant; 2. SCL Score > 0.5; Exclusion criteria:; 1. Not a new episode of antidepressant treatment; 2. Bipolar; 3. Schizophrenia; 4. Planning or receiving psychotherapy; 5. Cognitive, language, or hearing impairment | Intervention description: Three arms:; 1. Telephone-based psychotherapy (CBT) + CM: 195 participants; 2. Telephone CM: 207 participants; 3. Usual care: 195 participants; Depression intervention(s): [underlined: Behavioral intervention] Type: CBT; 8 sessions structured assessment, motivational enhancement, behavioral activation, cognitive restructuring, self-care plan Delivery: Telephone Intensity: 8 sessions 30 to 40 min; first four sessions every wk, second four 1 to 4 wk apart Fidelity monitoring: No Other notes about intervention: Psychotherapy was in addition to CM [underlined: Therapist] Discipline: Master's-level psychologist Experience: At least 1 yr clinical experience Training: 12 hr didactic and role play, observation, and audiotaping of 6 sessions each, 1 hr weekly supervision, twice monthly motivational interviewing seminar Comparator 1: Behavioral control Type: Usual care; any treatment normally available including primary care physician visits and referral to mental health Delivery: NR Intensity: NR Fidelity monitoring: No Comparator 2: [underlined: Behavioral control] Type: Telephone CM; assessment of depression, antidepressant use, and adverse effects. Scripts for addressing concerns and motivational enhancement. Primary care physicians received summary and computer-generated recommendations. Also care coordination, outreach, and as-needed crisis intervention. Delivery: Telephone Intensity: Wk 4, 12, 20 Fidelity monitoring: No Cointervention—psychotropic drugs: NR | Eligible randomized: 95% Followup rate: N (%) 578 (96%) had 1 followup 532 (89%) completed 6 month followup CM: 97% had 1 contact 85% had 3 contacts Psychotherapy + CM: 14 (7%) had no sessions 2 (1%) had 1 session only 167 (84%) had ≥ 4 sessions 125 (25%) had ≥ 7 sessions Important baseline differences: None Depression outcomes: 6-mo followup using SCL (50% reduction) Response rates n (%): Usual care: 76 of 176 (43%) CM: 94 of 184 (51%) Psychotherapy + CM: 100 of 172 (58%) Severity score: NR HRQOL outcomes: NR Other outcomes: NNT 6.4 for 50% reduction in SCL psychotherapy + CM versus usual care Social: NR Occupational: NR Satisfaction: Self-rated “very satisfied”— Usual care: 50 of 176 (29%) CM: 85 of 184 (47%) Psychotherapy + CM: 101 of 172 (59%) Self-rated “much improved”— Usual care: 97 of 176 (55%) CM: 121 of 184 (66%) Psychotherapy + CM: 100 of 172 (58%) Total depression costs: $ Mean (SD) Usual care: 1020 (1009) CM: 1485 (1258) Psychotherapy + CM:1670 (1110) Total health care costs $ Mean (SD) Usual care: 9406 (10554) CM: 10268 (9773) Psychotherapy + CM: 9334 (8432) Treatment discontinuation rate: N (%) 14 (7%) had no sessions 2 (1%) had 1 session only 167 (84%) had ≥ 4 sessions 125 (25%) had ≥ 7 sessions Adverse effects: NR | General comments: None Study-level quality assessment: Good Comments:; - Comparable groups; - Little missing data; - Outcome assessors blinded; - Not free of selective outcome reporting; - PHQ results not reported; - SCL scores at outcome not reported; Assessment of adverse effects adequate? NR Applicability:; - Severity of baseline depression, chronicity and comorbid condition not given; - Sample was from a group model primary care clinic who did not want referral to mental health clinic; - CM involved significant outreach (at least 5 phone calls) per participant, which is not routine clinical practice

Study ID: Wilson, 1982

Study Information | Participants | Interventions | Results and Adverse Effects | Comments/Quality Scoring
Geographical location: Sydney, Australia Recruitment method: Advertisement Recruitment setting: Mental health Treatment setting: Academic Study design: RCT, stratified by sex Number of participants enrolled: 97; 64 analyzed Duration of followup:; - 8 wk; - 6 mo posttrial followup | Age: Mean (SD): 38.8 (NR) Median: NR Range: 20 to 55 Education: NR Sex: Female: 42 (65.6%) Race/ethnicity: NR Veterans: None Baseline depression assessment(s): Criterion: BDI Disorder: NR Severity: Amitriptyline + task assignment: 26.08 (7.61) Amitriptyline + relaxation therapy: 23.10 (3.51) Amitriptyline + minimal contact: 25.8 (5.12) Placebo + task assignment: 27.22 (4.87) Placebo + relaxation therapy: 25.82 (4.47) Placebo + minimal contact: 25.00 (5.77) Chronicity: NR Prior episodes: “Past psychological issues in 86%” Comorbid psychiatric conditions: NR Comorbid chronic medical conditions: NR Inclusion criteria:; 1. BDI ≥ 20; 2. Depression ≥ 2 months (self-report); Exclusion criteria:; 1. No other major psychiatric disorders; 2. Not getting any psychological or pharmacological treatments (apart from minor tranquilizers); 3. No contraindications to amitriptyline | Intervention description: Patients randomly allocated within sex to:; 1. Amitriptyline + task assignment; 2. Amitriptyline + relaxation therapy; 3. Amitriptyline + minimal contact; 4. Placebo + task assignment; 5. Placebo + relaxation therapy; 6. Placebo + minimal contact; Depression intervention(s): [underlined: Behavioral intervention] Type: Behavioral therapy, 7 sessions over 1 hr Delivery: Individual Intensity: NR Fidelity monitoring: NR Other notes about intervention: Adapted from MacPhillamy and Lewinsohn therapy [underlined: Therapist] Discipline: Psychology Experience: Graduate students Training: Previous experience with behavioral treatments (experimental and clinical) not specified further Comparator: [underlined: Behavioral control] Type: Minimal contact, participants described their problems, nondirective and no specific suggestions Delivery: Individual Intensity: Two 1-hr sessions Fidelity monitoring: NR Other notes about control: Described as a way for subjects to talk about their problems and see a solution to it themselves Cointervention—psychotropic drugs: Drug name/dose: Randomized to drug or placebo. Amitriptyline 50 mg titrated to 150 mg over 6 wk and then titrated off over 6 days Clinician discipline: NR | Eligible randomized: 97; 64 analyzed in completers analysis Followup rate: 64 (65.9%) Important baseline differences: None Depression outcomes: 8 wk: Placebo + task assignment: 11.89 (10.87) Placebo + relaxation therapy: 16.55 (10.36) Placebo + minimal contact: 14.67 (11.12) 6 mo: Placebo + task assignment: 10.00 (8.14) Placebo + relaxation therapy: 11.27 (7.98) Placebo + minimal contact: 15.18 (10.86) Response rates: NR Severity score: NR HRQOL outcomes: NR Other outcomes: Social: No Occupational: No Satisfaction: No Treatment discontinuation rate: NR Adverse effects: NR | General comments: None Study-level quality assessment Poor Comments:; - Unclear randomization; - Unclear allocation concealment; - Incomplete data not addressed; - Unclear blinding (not blinded to drug); - Selective outcome reporting; Assessment of adverse effects adequate? No Applicability: [underlined: To general population:]; - Done in Australia; - University setting; - Recruitment via advertising; [underlined: To Veterans:]; - 65% women; - Comorbidities NR; - Chronicity NR

Study ID: Wilson, 1983

Study Information | Participants | Interventions | Results and Adverse Effects | Comments/Quality Scoring
Geographical location: Sydney, Australia Recruitment method: Advertisement Recruitment setting:; - Mental health, primary care, mixed; - Nonclinical; Treatment setting:; - Mental health outpatient; - Academic; Study design: RCT Number of participants enrolled: 25 Duration of followup:; - 8 wk; - Naturalistic followup of interventions at 30 wk | Age: Mean : 39.5 Median: NR Range: 20 to 58 Education: 19 (76%) completed at least lower secondary school Sex: Female: 20 (80%) Race/ethnicity: NR Veterans: No Baseline depression assessment(s):; - 7 participants had past hospitalization; - 2 on antidepressants; - 3 on minor tranquilizers; Behavioral therapy arm Criterion: BDI Disorder: NR Severity: 21.13 (7.62) Chronicity: At least 3 mo Prior episodes: NR Criterion: HAM-D (17 item) Disorder: NR Severity: 13.89 (3.22) Chronicity: at least 3 mo Prior episodes: NR Cognitive therapy arm Criterion: BDI Disorder: NR Severity: 27.25 (3.80) Chronicity: At least 3 mo Prior episodes: NR Criterion: HAM-D (17 item) Disorder: NR Severity: 13.62 (2.40) Chronicity: At least 3 mo Prior episodes: NR | Intervention description:; 1. Behavioral therapy: 8 participants; 2. Cognitive therapy: 8 participants; 3. Waitlist: 9 participants; Depression intervention 1: [underlined: Behavioral intervention] Type: Behavioral activation based on Lewinsohn et al. To increase the frequency, quality, and range of activities and social interactions; mood record also maintained. Delivery: Individual Intensity: Eight 1-hr weekly sessions Fidelity monitoring: No Depression intervention 2: [underlined: Cognitive intervention] Type: Cognitive restructuring based on Beck et al. Negative cognitive distortions and irrational beliefs evaluated and positive thought schedule developed for 3 times a day use; thought record also maintained. Delivery: Individual Intensity: Eight 1-hr weekly sessions Fidelity monitoring: No [underlined: Therapist] Discipline: NR Experience: NR Training: NR Comparator: [underlined: Behavioral control] Type: Waitlist only; no interaction Delivery: None Intensity: None Fidelity monitoring: No Cointervention—psychotropic drugs: NR Waitlist Criterion: BDI Disorder: NR Severity: 23.66 (7.45) Chronicity: at least 3 mo Prior episodes: NR Criterion: HAM-D (17 item) Disorder: NR Severity: 13.62 (4.08) Chronicity: At least 3 mo Prior episodes: NR Comorbid psychiatric conditions: Excluded Alcohol/substance abuse: NR PTSD: NR Other anxiety disorder: NR Other: NR Comorbid chronic medical conditions: NR Inclusion criteria:; 1. BDI ≥ 17; 2. Frequent episodes of depression (self-report); 3. Depression for at least 3 mo (self-report); Exclusion criteria:; 1. Previous/concurrent use of major tranquilizers or lithium; 2. No other major physical or psychiatric disorders; 3. No suicidal ideation | Eligible randomized: 29 Followup rate: NA; 3 participants in behavioral treatment and 1 in cognitive treatment dropped out and were replaced by new participants Important baseline differences: NR Depression outcomes: Response rates: NR Severity scores: BDI Behavioral therapy Pre Rx: 21.13 (7.62) Post Rx: 7.50 (4.55) Cognitive therapy Pre Rx: 27.25 (3.80) Post Rx: 9.00 (6.82) Waitlist Pre Rx: 23.66 (7.45) Post Rx: 21.44 (5.52) HAM-D Behavioral therapy Pre Rx: 13.89 (3.22) Post Rx: 5.25 (3.46) Cognitive therapy Pre Rx: 13.62 (2.40) Post Rx: 5.88 (5.01) Waitlist Pre Rx: 13.22 (4.08) Post Rx: 14.78 (5.96) HRQOL outcomes: NR Other outcomes: Social: No Occupational: No Satisfaction: No Treatment discontinuation rate: 3 of 8 (37.5%) participants in behavioral treatment and 1 of 8 (12%) in cognitive treatment dropped out and were replaced by new participants Adverse effects: NR | General comments: None Study-level quality assessment Fair Comments:; - Unclear randomization; - Unclear allocation concealment; - Unclear blinding; - No selective outcome reporting; - Patients who dropped out were replaced; possibly not randomized; - Comorbidities NR; - Limited information reported, but an old study; Assessment of adverse effects adequate? No Applicability: [underlined: To general population:]; - Recruited via advertising; - Treated in Australia; - Treatment in a university setting; [underlined: To Veterans:]; - 80% women; - No comorbidities reported including substance abuse; - Dropouts replaced

Abbreviations: AE = adverse effects, BDI-II = Beck Depression Inventory-II, CBT = cognitive behavioral therapy, CES-D = Center for Epidemiologic Studies-Depression Scale, CI = confidence interval, DIS = Diagnostic Interview Schedule, HDRS = Hamilton Depression Rating Scale, MDD = major depressive disorder, n = number, NA = not applicable, NR = not reported, ns = not significant, OR = odds ratio, p = probability, PHQ = Patient Health Questionnaire, RCT = randomized controlled trial, SD = standard deviation, SE = standard error, ST = standard treatment, vs = versus, wk = week/weeks, yr = year/years

## LIST OF INCLUDED STUDIES FROM PRIMARY LITERATURE IN ALPHABETICAL ORDER

Barnhofer T, Crane C, Hargus E, et al. Mindfulness-based cognitive therapy as a treatment for chronic depression: A preliminary study. Behav Res Ther. 2009;47(5):366-73. [pmid: 19249017].
Laidlaw K, Davidson K, Toner H, et al. A randomised controlled trial of cognitive behaviour therapy vs treatment as usual in the treatment of mild to moderate late life depression. Int J Geriatr Psychiatry. 2008;23(8):843-50. [pmid: 18311844].
Mynors-Wallis LM, Gath DH, Day A, et al. Randomised controlled trial of problem solving treatment, antidepressant medication, and combined treatment for major depression in primary care. BMJ. 2000;320(7226):26-30. [pmid: 10617523].
Nezu AM. Efficacy of a social problem-solving therapy approach for unipolar depression. J Consult Clin Psychol. 1986;54(2):196-202. [pmid: 3700806].
Simon GE, Ludman EJ, Tutty S, et al. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: a randomized controlled trial. JAMA. 2004;292(8):935-42. [pmid: 15328325].
Simon GE, Ludman EJ, Rutter CM. Incremental benefit and cost of telephone care management and telephone psychotherapy for depression in primary care. Arch Gen Psychiatry. 2009;66(10):1081-9. [pmid: 19805698].
Wilson PH. Combined pharmacological and behavioural treatment of depression. Behav Res Ther. 1982;20(2):173-84. [pmid: 7073647].
Wilson PH. Comparative efficacy of behavioral and cognitive therapies of depression. Cognit Ther Res. 1983;7(2):111-124.