# SEARCH STRATEGY

Primary Literature (January 2009 through July 2010)

Final limits: Human, Adult, 19+ years, English, Randomized Controlled Trial, Publication date from January 1, 2009 to July 31, 2010.

Step | Terms | Result
1. Replication of Cuijpers database therapy terms | Behavior therapy OR biofeedback OR cognitive analytic therapy PR counseling OR family therapy PR marital therapy PR psychoanalytic therapy OR psychotherapy PR relaxation therapy | 1822
2. Replication of Cuijpers database depression terms | “depressive disorder”[MeSH Terms] OR (“depressive”[All Fields] AND “disorder”[All Fields]) OR “depressive disorder”[All Fields] OR “depression”[All Fields] OR “depression”[MeSH Terms] OR depressive[All Fields] | 1152
3. Addition of other terms for types of therapy of interest for this report | Interpersonal therapy OR problem-solving therapy OR mindfulness-based cognitive therapy OR cognitive behavioral analysis system of psychotherapy OR dialectical behavior therapy OR functional analytic psychotherapy OR acceptance and commitment therapy | 178
4. Final search | (#1 OR #3) AND #2 | 383

Systematic Reviews

Final limits: English, All Adult: 19+ years, Systematic Reviews, Publication date from 2000.

Step | Terms | Result
1 | Search ((“depressive symptoms”[All Fields]) OR (“Depression”[Mesh] OR “Depressive Disorder”[Mesh]) OR (depression)) | 51523
2 | Search (minor AND depression) OR (subthreshold AND depression) OR (subsyndromal AND depression) | 3689
3 | Search major depressive disorder[mesh] | 64244
4 | Search dysthymia OR dysthymic disorder[mesh] | 2407
5 | Search adjustment disorder[mesh] | 3615
6 | Search 1 OR 2 OR 3 OR 4 OR 5 | 69903
7 | Search ((cognitive behavioral therapy OR CBT OR cognitive therapy OR behavior therapy OR interpersonal therapy OR IPT OR problem-solving therapy OR PST OR mindfulness-based cognitive therapy OR MBCT OR (“cognitive behavioral analysis system” AND therapy) OR CBASP OR dialectical behavioral therapy OR DBT OR functional analytic psychotherapy OR FAP OR (acceptance AND commitment AND therapy) OR ACT OR short-term psychodynamic therapy) OR (psychotherapy, brief[mesh])) | 297485
8 | Search Cochrane Database Syst Rev [TA] OR search[Title/Abstract] OR meta-analysis[Publication Type] OR MEDLINE[Title/abstract] OR (systematic[Title/Abstract] AND review[Title/Abstract]) | 159125
9 | Search 6 AND 7 AND 8 | 341