# RESULTS

## Literature Flow

The combined library contained 3252 citations, of which we reviewed 578 articles at the full-text level. From these, we identified systematic reviews and observational studies that addressed one or more of the key questions. Figure 2 shows the results of the literature search and the organization of themes that emerged for each key question.

Figure 2 Management of Pain in Polytrauma Literature Flow

## Key Question #1. Have reliable and valid measures and assessment tools been developed to measure pain intensity and pain-related functional interference among patients with cognitive deficits due to traumatic brain injury (TBI)? Which measures and tools are likely to be most useful in assessing pain in polytrauma patients with cognitive deficits due to TBI?

### Summary of findings

There were no published studies that assessed reliability and validity of measures of pain intensity or pain-related function among patients with cognitive deficits due to TBI.

### Secondary findings

- A number of primarily cross-sectional and case-control studies suggest that pain may interfere with neurocognitive functioning among TBI patients. Only some of these studies adjusted for potential confounders of the relationship between pain and neurocognitive performance.
- Several studies suggest that most individuals with cognitive impairment due to dementia can understand at least one pain self-assessment measure.

### Details of Studies—Secondary Findings

#### Pain may interfere with neuropsychological assessment among TBI patients

We identified several narrative review articles that addressed this topic in depth.(13–15) These review articles include a number of primarily cross-sectional and case control studies that found negative associations between headache pain and cognitive functioning among TBI and non-TBI patients. Most TBI patients in these studies had mild TBI. Most of these studies support that acute or chronic pain irrespective of whether a patient has TBI, is associated with worse cognitive performance. While cognitive effects associated with pain may be quite variable, attention, memory, speed of processing and executive control may be most strongly affected.(13) Of note, investigators have identified factors other than pain that have the potential to confound or modulate the relationship between pain and neurocognitive performance. Such factors include psychological distress, mood, or anxiety disorders,(16–18) somatic complaints and concerns,(19) and sleep deprivation.(20) Thus, it remains unclear to what extent pain remains negatively associated with neurocognitive functioning when potentially confounding factors are considered.

#### Assessment of pain in patients with cognitive impairment due to dementia

The recently published VA Evidence Synthesis Report entitled, “Assessment and management of acute pain in adult medical inpatients: A systematic review”(21), four additional published reviews (22–25), and a guideline for assessing pain in the elderly(26) have addressed assessment of pain in patients with cognitive impairment due to dementia. Together, these reviews indicate that there is limited evidence that most individuals with mild to moderate cognitive impairment due to dementia can understand at least one self-assessment pain measure. Among the existing scales of nonverbal behavioral pain indicators, none have been demonstrated to be substantially more reliable or valid than others for patients with cognitive impairment due to dementia. However, several of the reviews indicate that the Pain Assessment Checklist for Seniors with Limited Ability to Communicate (PACSLAC) may be especially promising or useful (27), and that the Discomfort Scale may have especially desirable psychometric properties.(28) To date, these self-assessment measures have not been specifically tested with TBI patients. Guidelines for assessing pain in patients with dementia who cannot understand any of the self-assessment measures suggest that multiple assessment methods may be best. Specific options include the use of an observational assessment measure, input from family, friends, or staff who know the patient well, and empiric pain treatment if the impaired patient has diagnoses usually associated with pain.(29–32)

## Key Question #2.A. Which treatment approaches are most likely to be effective in improving pain outcomes (pain intensity and functional interference) in polytrauma patients? B. Which pain treatment approaches are most likely to enhance overall rehabilitation efforts?

### Summary of findings

2A: There were no randomized controlled trials, systematic reviews, prospective cohort, case-control, or systematic observational studies that tested the efficacy or effectiveness of specific pain treatment approaches among patients with polytrauma.

2B: One fair-quality retrospective cohort study of patients who had undergone amputation at an urban trauma center demonstrated that after controlling for demographic factors, injury characteristics and other medical morbidity, inpatient rehabilitation was marginally associated with increased likelihood of return to work and decreased likelihood of reduced hours of work. (GRADE: Very Low)

### Secondary Findings

- One fair-quality systematic review of primarily case reports on patients with causalgia (now known as complex regional pain syndrome II) due to war-related injuries suggests that sympathetic blocks and sympathectomy are frequently effective treatments.
- A number of manuscripts presented cases or case series describing pain treatment approaches and pain outcomes among patients with polytrauma including TBI.

### Details of Studies—Primary Findings

One fair-quality retrospective cohort study of patients who underwent amputation at an urban trauma center between 1984 and 1994 examined factors that predicted whether a patient would receive inpatient rehabilitation and the success of treatment.(33) Seventy-eight patients (68% of eligible respondents) who had undergone trauma-related amputation at one hospital between 1984 and 1994 were contacted and interviewed an average of 7 years after their injuries. The study excluded amputation for non-injury reasons (e.g. diabetes), spinal cord injury or TBI. Many patients in the sample had multiple injuries. After controlling for demographic factors, injury characteristics and other medical morbidity, inpatient rehabilitation was marginally associated with increased likelihood of return to work (p=0.09) and decreased likelihood of reduced hours of work (p=0.05).

### Details of Studies—Secondary Findings

One fair quality systematic review on causalgia (now known as complex regional pain syndrome II) was published in 2003.(34) In this review, MEDLINE and Index Medicus were searched using the terms, causalgia and neuralgia. All references including new cases of causalgia were included. One hundred ten manuscripts describing a total of 1,528 cases of causalgia were identified. No information about any experimental or longitudinal observational studies beyond individual cases or case series was reported. Overall, 57% of cases were war-related and 67% of cases were due to high-velocity missiles. It is unclear to what extent the overall group had polytrauma, but we infer from the traumatic nature of the injuries that polytrauma was likely common. The median nerve and sciatic trunk were the nerves most commonly involved and the most prominent clinical manifestations were burning pain (86%) diaphoresis (73%), paresthesias (96%), and sensitivity to stimuli (98%). Response to sympathetic blocks was observed in 88%, and 94% of patients undergoing sympathectomy were described as cured.

A number of manuscripts presented cases or case series describing pain treatment approaches and pain outcomes among patients with polytrauma including TBI. This information is summarized in Table 1 below. Several case reports support that intrathecal baclofen may be helpful for spasticity associated with TBI and related injuries. Despite supplemental hand-searches within our reference library for manuscripts on the use of opioids in patients with polytrauma including TBI, we found only one case report documenting (positive) specific effects of opioids in a TBI patient (included in Table 1)

Table 1 Secondary Findings pertaining to Key Question 2: Case Reports/Case Series^*^

Study | Study Design/Sample | Condition(s) | Treatment Approach | Results
(35) | Single case | Severe TBI with brainstem seizures and pain | Mesothalamic electrode stimulation | Attenuated brainstem generated seizures and relieved chronic pain
(36) | Single case | TBI plus other injuries | Acupuncture | Decreased pain and anxiety
(37) | 100 consecutive referrals | SCI (includes 15 TBI patients) | Botulinum injections and physical therapy | Clinician-reported global improvement in 90% of patients
(38) | Single case | Complex regional pain syndrome I (formerly known as Reflex sympathetic dystrophy) post-amputation | Topical capsaicin | Associated with disappearance of pain and autonomic changes
(39) | 4 cases, one with TBI | Spasticity | Divalproex sodium (DVS) | Marked improvement in pain. One patient could not tolerate DVS
(40) | 12 cases, 6 with missile head injury | Anxiety and headache | Fluphenazine | Reductions in headache and anxiety
(41) | 2 cases, one with TBI | Central Pain | Gabapentin | Increased anxiety
(42) | Single case (OEF/OIF veteran) | Knee pain due to explosion, mild TBI, substance use disorder and PTSD | Multidisciplinary care including cognitive processing therapy | Decreased knee pain interference
(43) | 7 cases (veterans) (5 received comparator intervention) | SCI and neuropathic pain | Healing Touch | Variable response; overall improvement in pain and satisfaction with life
(44) | Single case | Heterotopic ossification in TBI | Indomethacin and Radiation therapy | No response to indomethacin, but decreased pain with radiation therapy
(45) | Single Case | TBI with heterotopic ossification | Intense physiotherapy after surgery | Improvements in pain and behavioral symptoms
(46) | 11 cases (8 with TBI) | Refractory spasticity | Intrathecal baclofen | Clinican-reported global improvement in all cases
(47) | 19 patients (4 with TBI) | SCI-related spasticity | Intrathecal baclofen | Spasticity and pain improved in 14 pts.
(48) | 9 cases (1 with TBI | Severe spasticity | Intrathecal baclofen | Most pts. improved, but no change in pain in TBI patient
(49) | 14 cases (5 due to trauma | Spastic hypertonia | Intrathecal baclofen | Decreased pain
(50) | 3 cases with TBI | Spasticity | Intrathecal baclofen | Decreased painful spasms
(51) | Single Case | TBI with unilateral central pain | Motor cortex stimulation | VAS change from 75–85 to 20–30; 50%–95% improvement in neuropathic symptoms
(52) | Single case | Severe TBI Schizophrenia | Opioid (oxycodone) | Increased interaction with others, decreased anxiety
(53) | Single case | Multiple medical conditions incl. polytrauma | Qigong Therapy | Decreased pain, weight loss, discontinuance of several medications
(54) | Single case | TBI with severe headache | Sphenopalatine Ganglion pulsed radiofrequency lesioning | Long term relief of intractable headaches
(55) | 10 consecutive cases (7 due to trauma) | Complex regional pain syndrome I | Spinal Cord Stimulation | Mean Numeric Rating Scale (NRS) pain score decrease of 6.2; decreased opioid use
(56) | Single case | Blast-related headache | Urea and chorionic gonadotropin | Headache free

* Subjects with TBI had moderate or severe TBI or TBI plus other injuries/complications

## Key Question #3.A. Does blast-related headache pain differ in terms of phenomenology and treatment from other types of headache pain? B. Which treatments are best for persistent blast-related headache pain?

### Summary of findings

There were no randomized controlled trials, cohort studies, case-control studies, or other systematic observational studies that compared patients with blast-related headache to patients with other types of headache or that specifically addressed treatments for blast-related headache pain.

### Secondary findings

- Three studies (57–59) addressed the prevalence of headache among patients reporting head injuries. In a cross-sectional study of Army infantry soldiers post-deployment to Iraq with mild-TBI, most related to blast, 32% of soldiers reporting loss of consciousness and 18% of those reporting altered mental status also reported headache.(57) In a cross-sectional study of soldiers with injuries from Iraq and Afghanistan, two-thirds of whom were exposed to blast, 91% reported post-concussive symptoms, and headache was present in 47% of patients in this group.(58) Finally, in a poor-quality cohort study of civilians injured by munitions explosives in Yugoslavia, one year after injury, 30% of patients with blast injuries reported a constellation of symptoms which included headache, vertigo, and psychological and cognitive sequelae.(59)
- Two cross-sectional studies described blast injuries of the ear including hearing deficits, otalgia, and mandibular pain.(60, 61) We include this information because these types of problems have the potential to complicate the assessment and treatment of blast-related headache. In a study of service members at Walter Reed Army Medical Center referred for audiologic testing for follow-up of blast exposure, age-adjusted hearing thresholds were significantly lower than expected, 32% of patients had experienced tympanic membrane perforation, 49% reported tinnitus, and 5% reported otalgia.(60) In a study of civilians from Iran with war-related blast exposure referred to an oral/maxillofacial surgery clinic for evaluation of mandibular problems, pain was a common complaint and levels of pain were associated with distance from blasts.(61)
- We identified one good quality systematic review of post-traumatic headache in TBI,(62) but blast exposure was not included as a characteristic in any of the studies, nor did the review explore relationships between TBI severity and headache (thus we include the results here as secondary findings). The review showed that most posttraumatic headache resolves within 6–12 months, but headaches persist beyond one year in 18% to 33% of patients. Many patients with posttraumatic headache have clinical presentations similar to tension-type headache or migraine. Many clinicians treat posttraumatic headache as if they are managing primary headache.

### Details of Studies—Secondary Findings

In a recent cross-sectional study assessing the prevalence and significance of self-reported history of combat-related mild TBI, soldiers from two US Army combat infantry brigades were surveyed three to four months after a yearlong deployment in Iraq in 2006.(57) Of 4,618 soldiers potentially eligible to participate, 2,714 (59%) completed surveys. The authors note that lack of availability to complete questionnaires was mostly due to normal transfers to other units, trainings or attendance at military schools. Surveys inquired whether soldiers had been injured during their deployments by a blast or explosion, a bullet, a fragment or shrapnel, a vehicle accident, or other means, and whether the injury involved the head. A soldier was considered to have mild TBI if he or she endorsed “losing consciousness,” “being dazed, confused or seeing stars,” or “not remembering the injury.” Multivariate logistic regression analyses were used to identify correlates of a range of self-reported outcomes including general health, missed workdays, medical visits, and somatic and postconcussive symptoms. Of soldiers reporting injuries with loss of consciousness or altered mental status, 75% reported being exposed to blast or explosion. Five percent reported injury with loss of consciousness, 10% reported in juries with altered mental status, and 17% reported other injuries during deployment. Headache was common, present in 32% of those reporting injury with loss of consciousness and 18% of those reporting altered mental status, as compared to soldiers who reported other injuries (12%) or no injury (8%) (p<0.001). In models adjusted for demographics, mechanism of injury, blast exposure, post-traumatic stress disorder (PTSD), depression, combat intensity, and hospitalization, the odds of headache remained significantly greater in soldiers reporting loss of consciousness versus other injury: 2.38 (1.12–5.07). The odds of headache were not significantly greater in soldiers reporting altered mental status vs. other injury: 1.63 (0.92–2.90). Overall, the analyses show that, except for in the case of headache when there is loss of consciousness, the associations among TBI and physical health problems are no longer significant when PTSD and depression are included in models.

An abstract from a cross-sectional study described the characteristics of soldiers returning from Iraq or Afghanistan who were injured in a blast, fall, gun shot wound, or motor vehicle accident, and screened for TBI by the Defense and Veterans Brain Injury Center (DVBIC) of Walter Reed Army Medicine Center between January 2003 and April 2005.(58) The sample included the initial 433 patients seen by the DVIBC. The sample was 95% males, modal age 21. Sixty-eight percent reported blast exposure, 79% reported loss of consciousness less than one hour, and 43% reported post-traumatic amnesia less than 24 hours. Ninety-one percent of patients reported post-concussive symptoms. Headache (47%), memory deficits (46%), and irritability/aggression (41%) were the most common post-concussive symptoms.

A poor-quality cohort study of 1,303 civilians who had been injured by munitions explosives in Yugoslavia between 1991 and 1994 and admitted to the US Military Medical Academy in Belgrade assessed the effects of blast exposure within one year of injury.(59) Approximately 30% of patients with 665 blast injuries reported persisting symptoms including headache, vertigo, positive Romberg’s sign, retrograde amnesia, mental blockage, apathy/lethargy, psychomotor agitation, and anxiety. The study was limited by inadequate reporting on rates of follow-up, timing of follow-up assessment, or details of the measurement of these symptoms.

An observational study that sought to examine whether blast was related to significant hearing changes collected audiologic data on 258 service members.(60) The investigators also explored whether polytraumatic injuries were associated with hearing loss. Potential subjects were referred for audiologic testing at Walter Reed Army Medical Center as part of a standard protocol for soldiers reporting at least one blast-related exposure. Only 162 out of 258 patients (63%) had hearing test data available for review. The mean age was 29 years and 98% were male. Within this group, age-adjusted actual hearing thresholds were significantly lower than expected, and 32% of patients had experienced tympanic membrane perforation, 49% reported tinnitus, and 5% reported otalgia. There was no association between polytrauma status and other characteristics. A cross-sectional study of 495 civilians with blast exposure who were referred to an oral/maxillofacial surgery clinic from the Medical Services Centre for War Injured Patients in Tehran, Iran between March 1984 and February 1990 reported that pain was a common complaint and that levels of pain were associated with distance from blasts.(61) In 115 patients, pain was localized in the external acoustic meatus and 15 patients complained of total facial pain. Forty-nine percent of the sample “responded” to limiting jaw movement, adopting a soft-diet, and the use of “pain killers,” and 77% responded to a combination of “pain killers” and muscle relaxants. Patient characteristics and the timing and methods to measure outcomes were not specified.

Finally, we identified one good quality systematic review of post-traumatic headache in TBI.(62) In this review, the investigators searched MEDLINE for literature on posttraumatic headache published between January 1990 and February 2005. Five studies specifically describing patient characteristics and types of headache were identified.(63–67) The total number of subjects in these studies was 423 patients. Blast exposure was not included as a characteristic in any of the five studies, and the review did not explore relationships between TBI severity and headache. The review showed that posttraumatic headache usually resolves within 6–12 months, but that 18% to 33% of the time, headaches persist beyond one year. Many (37%) of patients with posttraumatic headache had clinical presentations similar to tension-type headache or migraine (29%). Many clinicians treat posttraumatic headache as if they were managing primary headache. The authors conclude that there is no universally accepted protocol for treating posttraumatic headache, and that randomized controlled trials are needed in this area.

## Key Question #4. What patient factors are associated with better and worse (pain-related) clinical outcomes among polytrauma patients? Have interventions been developed to specifically address these factors?

### Summary of Findings

There were no randomized controlled trials. One systematic review, 11 cohort, 2 case-control, and 17 cross-sectional studies specifically addressed patient factors associated with outcomes in TBI patients. Twenty cohort, 2 cross-sectional, and 5 case-control studies addressed patient factors associated with outcomes in other polytrauma patients. Evidence Table 1 in Appendix E shows the data abstracted from these studies.

#### Traumatic Brain Injury

- One recent fair-quality systematic review showed that overall, 58% of patients with TBI have chronic headache, and that brain injury is associated with headache even after adjustment for post-traumatic stress disorder (PTSD).(68) These findings are consistent with our review, which included additional manuscripts, which found that among patients with TBI, headache is present in one-third to one-half of patients up to five years after injury. (GRADE: Low)
- The recent fair-quality systematic review above also found that patients with mild TBI were more likely to have headache than patients with moderate or severe TBI.(68) However, our review showed very mixed findings regarding the association between severity of TBI and pain (GRADE: Very Low).
- Psychological factors, including depression and posttraumatic stress disorder (PTSD), insomnia and fatigue are associated with pain in TBI patients. (GRADE: Low)

#### Other injuries in polytrauma patients

- Characteristics of injuries (location, severity, and whether they are multiple) are associated with clinical outcomes including persistent pain and functional status. Specific factors associated with worse pain-related outcomes include: multiple injuries, foot injuries or injuries below the knee joint, and concurrent head injury or cognitive disability. (GRADE: Low)
- Other factors associated with better outcomes in some studies of patients with polytraumatic injuries other than TBI were younger age, higher educational achievement, having a white collar job or higher income. (GRADE: Very Low)

### Details of Studies—Traumatic Brain Injury

#### Prevalence of pain and headache among TBI patients

One fair-quality systematic review was published in 2008. In this review, Ovid/MEDLINE, PubMed, and MD consult databases were searched using the terms brain injury, pain, headache, blast injury, combat, combat disorders, war, military medicine, wounds and injuries, military personnel, and veterans. The Cochrane Collaboration, National Institutes of Health Clinical Trials Database, Meta-register of Current Controlled Trials and CRISP database were searched using the term brain injury. Articles were included which were published between 1951 and February 2008 (however one article from 1939 is also included in the review.(69) The search was not limited by language or publication status. Case reports and review articles were cited only if no other data were available. Twenty-three studies (15 cross-sectional, 5 prospective observational, and 3 retrospective observational) including 4,206 patients were identified. No randomized clinical trials were identified. Data were pooled across studies to obtain overall prevalence rates. The review showed that 58% (95%CI 55.5–60.2%) of patients with TBI have chronic headache, and that brain injury is associated with headache even after adjustment for post-traumatic stress disorder (PTSD).(68)

In our review, we found seven prospective and one retrospective cohort studies that report on the prevalence of pain and headache among TBI patients.(70–77) In a good-quality prospective cohort study of 146 patients enrolled in acute inpatient rehabilitation for TBI, 73% reported pain at one year and 55% reported interference from pain.(71) One fair-quality prospective cohort study measured prevalence and type of headache among 109 patients with moderate to severe TBI consecutively admitted to one of four VA Polytrauma Rehabilitation Centers (PRCs) over 12 months.(70) On admission, 38% of patients reported headache. Sixty-four percent of patients with headache reported no to mild levels of incapacitation from headaches. Among patients with headaches at admission, 54% reported persistent headache symptoms at six months, and of this group, 96% still had headaches at 12 months. Of patients without headache at admission, the majority remained headache free over 12 months. In a fair-quality prospective cohort study of 161 patients admitted to a brain injury rehabilitation unit, 62% reported some type of pain and 31% reported daily pain or continuous pain at six months.(72) Headache was the most frequently reported type of pain. In a fair-quality prospective cohort study of 231 patients admitted to three trauma centers in France with severe head injuries reassessed five years after injury, the prevalence of headache was 44 to 54%, significantly greater than 16% in a comparison group with lower limb injury but no TBI.(73) In a poor quality prospective cohort study of patients with TBI consecutively admitted to an inpatient urban rehabilitation program who completed follow-up assessments, headache prevalence increased from 31% 2 years post-injury to 42% 5 years post-injury.(76) In a poor-quality prospective cohort study of 132 patients consecutively admitted to an inpatient TBI rehabilitation center, 10% of patients had co-existing peripheral nerve injuries, and of these patients, 31% reported pain.(77) In a poor-quality retrospective cohort study of 200 patients admitted to an inpatient accident service, headaches persisted in 17 to 18% of cases 6 months after injury.(75) Finally, in another poor-quality retrospective cohort study, 58% of patients admitted to an Australian teaching hospital had headaches 5 years after TBI.(74)

Two fair-quality case-control studies demonstrated that pain is more common or more severe in TBI patients than other populations.(78, 79) One of these studies showed that overall pain scores were higher in a volunteer community sample of mild to severe TBI patients at least 12-months post-injury compared to a group of non-injured controls (17.2 vs. 10.1, on a scale of 0-78 using the McGill pain questionnaire, p=.013).(78) The other study showed that the prevalence of pain complaints was 59% in a sample of patients with TBI referred for neuropsychological assessment at a medical center versus 22% of non-TBI patients also referred for neuropsychological assessment (p<.001).(79)

Several cross-sectional studies also support that pain and headache are common among TBI patients.(57, 58, 80-86) In these studies, pain was present in 22% to 90% of patients. In one of these studies of young patients admitted to a brain injury rehabilitation ward in London an average of 25 weeks after injury, only 12% reported headache.(82) Headache was the most common type of pain complaint according to two of these studies.(81, 85) Another study found that reflex sympathetic dystrophy (now known as Complex Regional Pain Syndrome I) was present in 13 of 100 patients consecutively admitted to an inpatient brain injury unit.(84) Notably, in several(81, 85, 86) of the above studies, case status was established at the time of outpatient follow-up assessment; thus, patients with persisting pain complaints may be overrepresented in these samples.

Taken together these studies show that pain is common among patients with TBI, present in approximately one-third to one-half of patients up to five years after injury. One prospective cohort, and several cross-sectional studies suggest that headache is the most common pain complaint among TBI patients.

#### Relationship between severity of TBI and pain in TBI patients

One fair-quality systematic review was published in 2008. In this review, Ovid/MEDLINE, PubMed, and MD consult databases were searched using the terms brain injury, pain, headache, blast injury, combat, combat disorders, war, military medicine, wounds and injuries, military personnel, and veterans. The Cochrane Collaboration, National Institutes of Health Clinical Trials Database, Meta-register of Current Controlled Trials and CRISP database were searched using the term brain injury. Articles were included which were published between 1951 and February 2008 (however one article from 1939 is also included in the review.(69) The search was not limited by language or publication status. Case reports and review articles were cited only if no other data were available. Twenty-three studies (15 cross-sectional, 5 prospective observational, and 3 retrospective observational) including 4,206 patients were identified. No randomized clinical trials were identified. Data were pooled across studies to obtain overall prevalence rates. The review showed that among civilians, the prevalence of chronic pain was 51.5% (95%CI 49.8%–53.2%) among patients with mild TBI, compared with 32.1% (95%CI 29.3%–34.9%) among patients with moderate or severe TBI.(68)

In our review, which included a number of studies not included in the systematic review above, one fair-quality prospective cohort study of 109 patients admitted to one of four VA PRCs, no statistically significant relationships were identified between Glasgow Coma Scale (GCS) score, Loss of Consciousness (LOC), or duration of post-traumatic amnesia (all indicators of head injury severity) and posttraumatic headache prevalence.(70) One good-quality prospective cohort study of 146 patients enrolled in a University acute inpatient rehabilitation program similarly found that baseline GCS was not associated with pain status one year after injury.(71) In another fair-quality prospective cohort study of 231 patients admitted to French trauma centers with severe head injuries who were reassessed five years after injury, headache prevalence was not found to be significantly different according to head injury severity.(73) Patients with severe head injury were less likely to complete follow-up assessments due to deaths. In an additional prospective cohort study of 200 consecutive individuals admitted to an urban hospital with head injuries, headache persisting longer than two months was not more prevalent among patients with more severe head injuries than patients with milder head injuries.(87) Finally, a poor-quality retrospective cohort study of 200 patients admitted to an inpatient accident service found no differences in the prevalence of headache when comparing patients with mild head injury to those with moderate to severe TBI three and six months after injury.(75)

In a cross-sectional study of consecutive TBI patients seen in an outpatient brain injury clinic, over half of the sample reported chronic pain (primarily headaches), and there were similar rates of pain reports when comparing patients with mild TBI to patients with more severe TBI.(81) A retrospective review of the records of 200 consecutive cases of head injury admitted to the surgical wards of the Edinburgh Royal Infirmary similarly found no increase in headache prevalence among patients who had presented with milder head injuries.(88) Finally, in a cross-sectional examination of the validity of the SF-36 for characterizing outcome after multiple trauma, there were no differences in the SF-36 bodily pain scale based on severity of head trauma among patients discharged from trauma centers who did not have concurrent orthopedic injuries.(89)

However, one fair-quality retrospective cohort study,(90) one fair-quality case-control study (79) and five studies using cross-sectional designs(82, 85, 86, 91, 92) found a higher prevalence of headache among patients with mild TBI as compared to more severe TBI. In the retrospective cohort study of 228 patients a median of four years after being admitted to a university ICU for major trauma, patients with severe head injury were less likely to report problems with pain/discomfort (OR 0.31, 95% CI 0.15 – 0.64) after adjusting for retrospectively-patient-reported baseline levels of symptoms and functioning. However, patients with severe head injury were less likely to participate in the follow-up surveys. In five of case-control and cross-sectional studies, study samples were established from referrals or attendees of outpatient follow-up clinics for TBI. Generally, patients were seen in these follow up clinics between six months and two years after their injuries. In one of the studies, the sample consisted of patients admitted to a subacute rehabilitation unit on average 25 weeks post-injury,(82) and in the remaining study, it was unclear whether the study cohort was established at the time of injury or time of outpatient follow-up.(92) Overall, this group of studies found that patients with mild TBI who attend outpatient brain injury clinics are two to three times more likely to report headache than patients with moderate or severe TBI. However, the analyses in these studies were not adjusted for potential confounding factors, and specific reasons why patients were referred to or sought care in these settings were not specified or adjusted for in most of the studies.

In summary, there is very limited evidence showing that patients with mild TBI are more likely to have headache or other pain than patients without TBI. While one retrospective cohort, one case-control, and a number of cross-sectional studies suggest that patients with mild TBI may be more likely to have headache pain than patients with moderate or severe TBI, six prospective cohort studies and additional cross-sectional studies did not find such a relationship. In the single systematic review showing a difference in rates of pain across levels of TBI severity, data were pooled across studies using different patient samples and designs. Most of the studies identified in that review and in our review that found associations between milder head injury and headache were done in outpatient settings, up to several years post-injury, and did not adjust for potential confounders that may influence relationships between TBI severity and pain. On the other hand, most of the samples in the identified cohort studies were assembled at the time of admission to a hospital or inpatient rehabilitation setting. It is therefore likely that differences in sample composition contribute to the differences in findings between the cross-sectional and cohort studies; patients with mild TBI may be more likely to be referred to or attend outpatient follow-up appointments when they have bothersome or persistent symptoms such as headache.

#### Relationships between other patient factors and pain outcomes in patients with TBI

Demographics: There are mixed findings regarding the association between demographic factors and pain outcomes in TBI patients. In one good-quality prospective cohort study of 146 patients enrolled in a university acute inpatient rehabilitation program, pain one year after injury was significantly associated with being female and non-white; being non-white remained significantly associated with reports of pain at one year in a multivariate regression model (taking other factors into account).(71) However, a fair-quality cohort study of veterans at VA PRCs(70) and a cross-sectional study of outpatients referred for neuropsychological evaluation (93) did not detect significant associations between demographic factors and headache frequency.

Blast exposure: In a cross-sectional study of 188 service members admitted to one of four VA PRCs, blast exposure was not found to be a significant predictor of pain.(80)

Psychological factors: In a fair-quality prospective cohort study of 109 patients admitted to one of four VA PRCs, headache density (a measure combining headache-related incapacitation and frequency) at six and 12 months was associated with higher depression and anxiety levels among patients with persistent headaches, and among patients with delayed onset headaches.(70) In another good-quality prospective cohort study of 146 patients enrolled in a university acute inpatient rehabilitation program, depression one year after injury remained significantly associated with reports of pain at one year (taking other factors into account).(71) Depression was also found to be a significant factor mediating the relationship between pain and community participation. In a fair-quality prospective cohort study of 161 patients admitted to a tertiary care center brain injury rehabilitation unit, frequency but not severity of chronic pain was associated with PTSD (p<.05).(72) In a multivariate model including psychological factors, only avoidant coping style remained significantly associated with pain severity after controlling for PTSD severity. In a fair-quality prospective cohort study of 47 patients admitted to a regional trauma center, pain was found to be highly correlated with depression (r=.81) in post hoc analyses. Finally, in a cross-sectional study of 84 patients from eight outpatient Mid-west rehabilitation centers, in a model including perceived stress, impact of events, and litigation status, pain was significantly associated with depression (partial R^2^ = .07, p=.001).(94)

Fatigue and Insomnia: In a poor-quality prospective cohort study of 38 TBI patients admitted to an inpatient rehabilitation service, there were highly significant correlations between levels of fatigue and pain at one and 2 years post-injury (R=.49 and .62, respectively, p<.01).(95) Another fair-quality case-control study of community volunteers showed that fatigue was correlated with the SF-36 bodily pain scale in TBI patients (R=.389, p<.011).(78) In another fair-quality case-control study of patients referred to a university outpatient neuropsychology service, pain was highly associated with insomnia (p<.001).(79) In an additional cross-sectional study of Canadian community volunteers, pain frequency was significantly associated with insomnia in TBI patients; pain remained a significant predictor of insomnia in a multivariate model that included depression, severity of injury and fatigue.(96) Finally, in another cross-sectional study, pain was significantly associated with insomnia in TBI patients admitted to a comprehensive outpatient rehabilitation program; however, pain dropped out of a multivariate model in which presence of insomnia was the outcome.(97)

Taken together, this group of studies provides limited evidence that psychological factors, including depression and posttraumatic stress disorder (PTSD), insomnia and fatigue are associated with pain in TBI patients.

### Details of Studies —Other Injuries in Polytrauma Patients

Injury characteristics—amputations: Studies support that injury factors (location, severity, multiplicity) are often associated with pain-related outcomes in patients with amputations. In a fair-quality retrospective cohort study of 78 trauma-related amputation patients, many of whom had multiple trauma, greater initial severity of injury was associated with significantly worse self-reported physical functioning including bodily pain.(33) In another fair-quality retrospective cohort study, investigators studied 326 patients from Belgrade who experienced missile-caused peripheral nerve lesions, some of whom likely had multiple trauma.(98, 99) In multivariate analyses, three factors were significant predictors of pain up to five years after injury: type of pain syndrome (e.g., complex regional pain syndrome II or deafferentation pain), severity of initial nerve injury, and an absence of pain paroxysms. In an additional fair-quality retrospective cohort study examining the long-term results of compartment syndrome, polytrauma patients were compared to those with a single injury.(100) The investigators did not find a difference with respect to strength, pain, or function and concluded that secondary injuries did not negatively impact the outcome of compartment syndrome. A poor-quality retrospective cohort study compared functional outcomes of Vietnam Veterans who had isolated transtibial amputations to those with amputations and at least one other major injury.(101) The polytrauma group scored significantly lower than the control group on all 8 subscale scores of the SF-36 including bodily pain, whereas quality of life scores from the single trauma group did not differ with those from the control group. A poor-quality quality case-control study compared 23 bilateral Vietnam Veteran amputees to age and gender matched controls from a national registry. Cases were surveyed an average of 28 years after injury. This study showed that while overall physical function was lower in the case group, bodily pain scores were not significantly different.(102) Finally, a cross-sectional study provided descriptive data on stump pain, phantom sensation, and phantom pain in 40 civilians from Sierra Leone who suffered traumatic upper limb amputation in a civil war setting.(103) Interviews were conducted 10–48 months post-injury. All amputees (100%) had stump pain in the last month and 93% had phantom sensations. Phantom pain was less common among patients with bilateral than unilateral amputations (18% versus 38%; no p-value reported). In an additional cross-sectional study of civilian amputees, stump and phantom limb pain were reported by 73% of multiple level amputees as compared to 63% of upper limb and 74% of lower limb amputees (no comparison significance tests reported).(104)

Injury characteristics—orthopedic injuries Studies also suggest that injury factors are associated with pain-related outcomes in patients with orthopedic injuries. A good-quality retrospective cohort study of 389 patients compared long-term functional outcomes among 3 groups, based on the site of fracture: above-knee, below knee, or combined fractures above and below the knee.(105) A mean of 17 years after injury (minimum 10 years), although persistent pain was not significantly more frequent among patients with below-knee fractures compared with above-knee fractures (46% v. 39%, p=0.25), persistent pain was significantly more common in patients with combined injuries as compared to fractures about the knee joint (58.5% vs. 39.3%, p<.001). Two additional small, fair-quality case-control studies compared functional outcomes in small numbers of polytrauma patients with and without foot injuries.(106, 107) In both studies, the outcomes of multiply injured patients with foot injuries were significantly worse than that of patients without foot injuries. Patients with foot injuries had a dramatically lower scores on SF-36 scales of physical function, role physical (perception of physical functioning), bodily pain, and social function compared to controls.(106, 107)

In another fair-quality prospective cohort study, 659 patients with multiple orthopedic injuries were compared to 165 patients with orthopedic injuries plus other types of injuries.(108) Six months post-injury, patients with combined orthopedic and other injuries had greater pain intensity and reported more disability than patients with multiple orthopedic injuries alone. A fair-quality retrospective cohort study compared pain and function in 27 long-term survivors of open pelvic fracture with the experience of 84 survivors of closed pelvic fracture.(109) Subjects were multiple system blunt trauma patients with a pelvic fracture, and associated injuries included head injury, thoracic trauma, abdominal injury, extremity fractures, and spinal fractures. Survivors of open pelvic fracture had non-significantly lower SF-36 bodily pain scores, and significantly lower scores for physical functioning and role physical subscales, indicating worse outcomes. Finally, a fair-quality prospective cohort study of orthopedic injuries was conducted in 830 polytrauma patients with spine injury.(110) Degree of injury severity was correlated with pain, functional independence, and return to employment one year and two years follow-up.

Injury characteristics—other polytraumatic injuries: A number of additional cohort studies examined relationships between various injury characteristics and functional outcomes including or in addition to measures of pain.(109, 111–120) Pain intensity was not a main outcome in these studies and was often measured using a subscale of a functional status measure. In only some of these studies were potentially confounding factors adjusted for in analyses involving pain outcomes.(113–115, 119) Most of the studies did not have excessive loss to follow-up, and some studies determined that patients lost to follow-up were not substantially different from patients represented in the study.(112, 113, 115, 116, 120) Almost all of the studies that compared multiply and singly injured patients to patients with a single injury, or measured the severity of injury, found an association between multiple or severe single injuries and worse functional outcomes and pain.(111, 112, 114–118) Some studies that included patients with cognitive disabilities or head injuries found associations between head injury or cognitive disability and decreased functional outcome.(112–115, 117) In an additional poor-quality case control study of 49 patients (setting not specified), patients with head injury plus other types of polytrauma were not found to have worse bodily pain at 6 or 12 months after injury compared to patients with TBI alone.(121) Finally, other injury characteristics associated with worse functional and pain outcomes were lower limb injuries,(114, 116, 120)longer hospital length of stay,(115) and admission to intensive care unit (ICU) and length of ICU stay.

In summary, many cohort studies as well as several case-control and cross-sectional studies found that polytraumatic injury characteristics (principally location, initial severity, and multiplicity of injury) are associated with pain and functional outcomes over time. Injuries below the knee joint are associated with worse outcomes compared to injuries above the knee in polytrauma patients. A number of these studies did not adjust for factors that may confound relationships between injury characteristics and pain-related outcomes.

Demographics: A number of manuscripts reported adjusting for demographic variables (mainly age) in multivariate analyses, but did not report whether and to what extent these variables were significantly associated with pain outcomes. One good-quality (115) and three fair-quality (33, 112, 118) cohort studies found associations between younger age and better functional outcomes in polytrauma patients. One good-quality cohort study (115) and one fair-quality cohort study (111) found associations between being male and better functional outcomes. In an additional cross-sectional study of 40 civilians from Sierra Leone who suffered traumatic upper limb amputation, phantom pain was more common in women than men (63% versus 25%, p=0.057).(103) However, in one fair-quality prospective cohort study of 62 patients injured in traffic accidents, there were no significant differences in SF-36 bodily pain scores by gender in bivariate analyses two and eight months post-injury.(122) Finally, in one fair-quality retrospective cohort study of 78 trauma-related amputation patients, being white was associated with better SF-36 PCS and bodily pain outcome scores, higher likelihood of return to work, and lower likelihood of reduced work hours.(33)

Other factors associated with better functional status were higher educational achievement (two good-quality (115, 119) and one fair quality (114) cohort studies), having a professional/white collar job (one good quality (119) and two fair-quality (112, 118) cohort studies) and higher income, job stability, job flexibility and lower physical demands at work (one good quality cohort study).(119) The authors of this latter study also found an association between receiving worker’s compensation and lower return to work rate.

Psychosocial Factors: Almost no studies reported on the relationships between psychosocial factors and pain-related outcomes in patients with polytraumatic injuries other than TBI. In one fair-quality retrospective cohort study of 69 patients admitted to an inpatient surgical service, loss of non-work activities was significantly correlated with pain.(112) One cross-sectional study provided descriptive data on stump pain, phantom sensation, and phantom pain 10–48 months post-injury in 40 civilians from Sierra Leone who had suffered traumatic upper limb amputation in a civil war setting.(103) No significant relationships were reported between mood and the prevalence of phantom or stump pain.

To summarize, there is very limited evidence regarding the extent to which demographic factors are associated with pain-related outcomes in patients with polytraumatic injuries other than TBI. Four cohort studies show that younger age is associated with better longer-term outcomes in patients with severe multiple injuries, and three cohort studies and one cross-sectional study show a relationship between male sex and improved outcomes after major trauma. There is almost no information available regarding relationships between race and ethnicity and pain-related outcomes. There is almost no information available regarding relationships between psychosocial factors and pain-related outcomes in patients with polytraumatic injuries other than TBI.

## Key Question #5. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers?

### Summary of findings

There were no randomized controlled trials, cohort studies, case-control studies, or other systematic observational studies that addressed provider and system barriers to detecting and treating pain among polytrauma patients. One qualitative study of providers from four VA Polytrauma Rehabilitation Centers (PRCs) addressed potential provider and system barriers to treating polytrauma patients.(3) In qualitative interviews, providers reported that polytrauma patients are very complex to treat, and that the work with this population is very challenging and emotionally taxing. Increasing use of multidisciplinary and concurrent care, and consultation from experts may be necessary to provide the complex care that is needed.

### Details of Study

This study was a qualitative study of provider perspectives on the rehabilitation of patients with polytrauma. This study which used Rapid Assessment Process methodology including semi-structured interviews, observation, and field liaison. The purpose of the study was to describe, from the perspective of providers working or affiliated with one of four VA Polytrauma Rehabilitation Centers (PRCs), 1) patients with combat-related polytrauma and their rehabilitation; 2) polytrauma patient family member involvement in rehabilitation; and 3) the impact on providers of providing polytrauma rehabilitation. Clinicians of various disciplines were selected among the four PRC sites, as well as personnel who work closely with the PRCs, including: 1) clinicians who provide regular consultation to PRC patients, including pain, PTSD, infectious disease, and low-vision specialists; 2) military liaisons who are US Department of Defense (DOD) employees housed at the PRC to help active-duty patients navigate across care systems; and 3) the VA points of contact who help US Service members obtain needed VA services; specific demographics of the clinicians interviewed were not provided. Fifty-six interviews were conducted.

A number of common themes were identified which are pertinent to this key question:

1. Patients with blast-related injuries including TBI have more injuries and more severe injuries than other patient populations. Serious psychiatric disorders, including PTSD and injury-related pain are highly prevalent, and complicate rehabilitation for TBI. These factors make this patient population quite complex to treat.
2. Providers find working with this population very challenging and emotionally taxing.
3. In order to address the level of complexity, providers are increasingly using co-treatment across disciplines, more regular consultation with services outside rehabilitation, such as surgery, amputation care, and psychiatry, and more frequent consultation with colleagues within and across the PRCs. PRC teams are expanding to include experts in areas including pain.
4. Spouses, parents, siblings, and children have become intensely involved in the injured service member's rehabilitation and have their own informational, instrumental, and support needs. Providers must respond to family needs and engage them as collaborators in the rehabilitation process.

## Limitations—Literature Review

### Heterogeneity and Generalizability

Due to innumerable etiologies and combinations of injuries, there is great heterogeneity among polytrauma patients. For example, within the category of blast-related head injury alone, there are multiple potential mechanisms of brain injury, and injuries may or may not be concurrent with other penetrating head injuries.(123) There is consequent heterogeneity among the study samples described in the literature as well as in the methods used to describe study samples. Many studies were done at single sites or within specialized types of settings. Thus, the conclusions we might draw from a particular study or set of studies may have limited relevance for other polytrauma patients, and comparisons among studies may be challenging.

### Scope

Due in part to the degree of heterogeneity among studies and their descriptions, as well as the lack of precision inherent in the term, “polytrauma”, we adopted a fairly stringent operational definition for polytrauma (multiple concurrent injuries in two or more systems) and focused on identifying studies that clearly included majorities of patients with polytrauma in their samples. Thus, for example, some studies of patients with spinal cord injuries or amputations were not included unless there was clear indication at the abstract or full-text level that multiple injuries were (often) involved. It is therefore likely that some manuscripts that might have relevance for the treatment of pain in polytrauma or subgroups of polytrauma patients were not identified. Surgical approaches were excluded due to the heterogeneity of the conditions being treated with specific techniques. We did not feel that information generated from review of specific surgical approaches would be very generalizable to the polytrauma patient population as a whole. We note that we did search more broadly for studies pertaining to TBI and blast since there is particular relevance for a large segment of the OEF/OIF patient population.

### Publication Bias

Our search strategies were comprehensive and we evaluated a large number of studies for possible inclusion in the review. Two librarians independently searched the literature and their results were combined to form our reference library. While this process identified many manuscripts for potential inclusion in the review, it is possible that our search terms did not capture some relevant manuscripts, especially for older studies which might not have been indexed in databases as pertaining to polytrauma or multiple injury/trauma. We therefore included additional search terms pertaining to blast, TBI, and war, and relied extensively on reference lists of studies, review articles, editorials, and consulting experts to identify additional manuscripts for review.

### Study quality

We did not exclude individual studies based on quality rating alone. Thus the strength of our conclusions is inherently limited by the quality variation among included studies. We did make an effort to note particular methodologic limitations, and each cohort and case-control study was closely reviewed for overall quality using a rigorously developed approach. Although cross-sectional studies were not formally rated, methodologic limitations were often noted.

## RESULTS—ACTIVE RESEARCH

### Summary of findings

Nineteen relevant active or planned projects were identified and project data were collected on 18 of these projects. Pain measures constitute main outcomes in 8 of the studies, and will be collected as secondary outcomes in 10 of the studies. Fifteen of the studies should generate information regarding patient factors that may contribute to pain-related outcomes among polytrauma patients (Key Question 4), and 4 studies are testing interventions for pain among polytrauma patients (Key Question 2). One study will test the reliability and validity of measures to assess pain in cognitively-impaired TBI patients and another study is using primarily qualitative methods to examine the utility of a CPRS pain assessment template module to assist clinicians in evaluating pain in PRC patients with cognitive impairment (Key Question 1). One study is examining the phenomenology and treatment of blast vs. other types of headache (Key Question 3), and one study is addressing provider and systems barriers to detecting and treating pain in polytrauma patients (Key Question 5).

### Details of findings

Email communications were sent to a total of 73 individuals, 4 VA workgroups (via their chairs), and 5 HSR&D portfolio managers, inquiring about possible projects the addressing key questions and inquiring about identifying others who might be doing or planning research relevant to the key questions. Individual email recipients included 41 VA investigators, 5 Department of Defense (DOD) investigators, and 27 non-VA, non-DOD investigators. Responses were received from 47 investigators. Nineteen relevant projects were identified and project data were collected on 18 of these projects. Table 2 on the following pages lists the ongoing studies for which data were available. The characteristics of these studies are described in further detail in Appendix E, Evidence Table 2.

Table 2 Summary of active research studies of pain in polytrauma

Title of Project | Main objective(s) of project | Pain-related variable(s) main or secondary outcome? | Study characteristics | KQ
Concurrent Validity of 4 Pain Intensity Scales in persons with Polytrauma and Cognitive Impairment(124) | Examine the concurrent validity of four pain intensity scales in the traumatic brain injury (TBI) inpatient rehabilitation population | Main | Study design: prospective randomized measurement study Sample: 15 TBI patients | 1
Pain Assessment in Polytrauma Rehabilitation Centers (PRCs)(125) | Evaluate utility of CPRS pain assessment templates, modify education materials; develop pain reports for clinicians and pain assessment database; identify best practices for pain care | Main | Study design: Qualitative Sample: Providers and nursing staff in two PRCs | 1,5
Evaluation of Stepped Care for Chronic Pain (ESCAPE)(126) | Compare a stepped care intervention vs. usual care in OIF/OEF veterans with chronic and disabling musculoskeletal pain | Main | Study design: RCT Sample: 300 OIF/OEF veterans | 2,4
The ViRTICo Trial: Virtual Reality Therapy & Imaging in Combat Veterans(127) | Compare effects of Virtual Reality Exposure Therapy & Imaging compared with Prolonged Exposure (current first-line therapy) | Secondary | Study design: controlled clinical trial Sample: OEF/OIF veterans with PTSD and TBI combined; PTSD alone; TBI alone; neither PTSD or TBI. | 2,4
Regional Anesthesia Military Battlefield Pain Outcomes Study(128) | Determine short-term and long-term pain- related outcomes in OEF/OIF veterans with traumatic extremity injuries; evaluate efficacy of early aggressive advanced regional anesthetic interventional techniques 2-yrs post-injury | Main | Study design: prospective cohort Sample: OEF/OIF soldiers with one or more maligned or amputated limbs | 2,4
Chronic Headache among OEF/OIF Veterans Exposed to Blasts(129) | Evaluate initial characteristics and treatment of blast-TBI in OEF/OIF veterans; assess feasibility and effectiveness of brief cognitive- behavioral headache management treatment (BCBHMT) | Main | Study design: case series Sample: OEF/OIF veterans | 2,3
Headaches in veterans returning from Iraq/Afghanistan: relation to trauma and combat-related injury(130) | To determine the relationship between Post- Traumatic Stress Disorder (PTSD), TBI, self- report of headaches, and combat-related injury in Operation Enduring Freedom (OEF) and Operation Iraqi Freedom (OIF) veterans | Main | Study design: Cross- sectional Sample: 343 male and female veterans registering for care | 4
Long-term Outcomes in Burned OEF/OIF Veterans (LOBO)(131) | Assess long term outcomes in OEF/OIF veterans with combat burn injury, combat nonburn injury, and in civilian burn patients | Secondary | Study design: Prospective cohort Sample: OEF/OIF veterans | 4
Women Veterans Cohort Study(132) | Assess health care utilization, costs, stress, and satisfaction in OEF/OIF veterans | Secondary | Study design: Prospective cohort Sample: OEF/OIF veterans | 4
Pain and Emotional Disorders in Veterans with and without Polytrauma(133) | Describe the prevalence, types, and course of pain and psychiatric disorders, as well as functional outcomes, among OEF/OIF vets with and without polytraumatic injuries | Main | Study design: Prospective cohort Sample: 150–200 polytrauma and 300–400 non-polytrauma OEF/OIF veterans | 4
Multidiscipline Assessment of Blast Victims for Cognitive Rehabilitation(134) | Determine whether blast exposure is associated with neuropsychological deficits and/or psychiatric disorder and identify contributors to blast-related post-concussive syndrome | Secondary | Study design: Prospective cohort Sample: OEF/OIF veterans | 4
Telerehabilitation of OEF/OIF combat wounded with TBI(135) | Provide care coordination and monitor functional and cognitive outcomes of 45 veterans discharged from a VA PRC with TBI; monitor for adverse effects of pain medication | Secondary | Study design: Prospective cohort Sample: OEF/OIF veterans with TBI | 4
Predicting Rehabilitation Costs for VA Patients with Traumatic Brain Injury(136) | Compare cost for rehabilitation for veterans with combat TBI to veterans with non-combat TBI; compare utility of measures in predicting costs; examine affect of PTSD on outcomes/costs | Secondary | Study design: Retrospective cohort Sample: OEF/OIF patients with TBI | 4
Characterization and Care Coordination of Polytrauma Patients(137) | Study & describe characteristics of polytrauma patients, including cognitive, emotional, physical and overall functional impairment | Secondary | Study design: Cross-sectional Population: OIF/OEF patients | 4
Pain, mental health, and daily function in OIF/OEF veterans(138) | Describe the pain concerns of OIF/OEF veterans, examine association between pain, comorbid mental health concerns, and daily functioning | Main | Study design: Cross-sectional Sample: 233 OIF/OEF veterans | 4
Clinical Characteristics of Patients with Polytrauma and Blast-Related Injuries(139) | Describe clinical characteristics, interventions and outcomes for inpatients with polytrauma and blast-related injuries (Assessment and treatment = primary) | Main | Study design: Cross-sectional Sample: Veteran inpatients at 4 PRCs | 4
Evaluation of Polytrauma Pain(140) | Retrospectively examine pain experiences of soldiers and veterans with polytraumatic injuries incurred during OIF/OEF | Primary | Study design: Cross-sectional Sample: OIF/OEF veterans | 4
Validity and reliability of proton magnetic resonance spectroscopy as a diagnostic and outcome measure in clinical trials involving people with SCI(141) | Determine the validity and reliability of Magnetic Resonance Spectroscopy (MRS) as a diagnostic and outcome measure for clinical trials of SCI chronic pain populations; to improve the management of chronic neuropathic pain following SCI | Secondary | Study design: Measurement study Sample: 60 persons with SCI and chronic neuropathic pain, 25 persons with SCI without neuropathic pain, and 25 healthy controls | 4

One study is addressing assessment of pain in cognitively impaired patients due to TBI (Key Question 1) using a prospective randomized measurement study of four pain intensity scales in persons with polytrauma and cognitive impairment.(124) Another study will evaluate the usability and utility of CPRS pain assessment templates in two PRC sites; a template contains a module designed to assist clinicians in evaluating pain in patients with cognitive impairment.(125)

Four studies are testing interventions in patients with polytrauma (Key Question 2): Bair is using an RCT design to test a stepped care intervention for OEF/OIF veterans with chronic and disabling musculoskeletal pain.(126) It is expected that some enrollees will meet criteria for polytrauma. Gallagher’s prospective cohort study will evaluate the efficacy of early advanced regional anesthetic techniques on pain and mental health outcomes two years post-injury.(128) Using a pre-post evaluation design, Gironda is piloting a brief cognitive headache management intervention for OEF/OIF veterans suffering from persistent blast-related headache.(129) In a controlled clinical trial, Roy is testing whether the Virtual Reality Exposure Therapy and Imaging intervention improves measures of functional health and disability compared to prolonged exposure therapy among veterans with PTSD and TBI.(127)

One study is examining clinical characteristics of headache conditions among OEF/OIF veterans referred to a VA Blast Injury Clinic (Key Question 3).(129) Thirteen studies will provide information about patient factors associated with outcomes in polytrauma patients (Kew Question 4). Six studies utilizing prospective cohort designs (128, 131–135) and one study using a retrospective cohort design (136) will follow samples of OEF/OIF soldiers or OEF/OIF veterans over time; outcomes include measures of pain, functional status, or adverse effects of pain treatments. Two clinical trials (126, 127) and 5 cross-sectional studies (130, 137–140) will also generate information regarding the relationship of patient factors to pain outcomes in polytrauma patients. An additional study is likely to include polytrauma patients and will examine the validity and reliability of Magnetic Resonance Spectroscopy as a diagnostic tool for clinical trials involving SCI patients with chronic pain.(141) A study objective is to determine pathophysiological and psychosocial contributors to pain after SCI.

Finally, in an ongoing study using qualitative and quantitative methods to evaluate the utility of CPRS pain assessment tools, information will be generated regarding provider or system barriers to treating pain among polytrauma patients (Key Question 5).(125)

## Limitations—Active Research

Although we made efforts to identify VA and non-VA investigators who are conducting or planning projects that address key questions, it is very likely that potentially relevant projects were not found. Our primary means of surveying was using email; many investigators did not respond to our queries, and we presume that in many of these cases, these investigators were not doing research relevant to the key questions. A snowball approach was used to identify relevant research projects; this approach identified several of the projects included in this review. We note that we communicated with several military/DOD and a number of non-VA, non-DOD investigators during the process. In addition, we searched a number of web-databases to identify funded VA and non-VA projects.