# REFERENCES

1 Lew HL, Poole JH, Vanderploeg RD, Goodrich GL, Dekelboum S, Guillory SB, et al. Program development and defining characteristics of returning military in a VA Polytrauma Network Site. J Rehabil Res Dev. 2007;44(7):1027-1034. [pmid: 18075959].
2 Gawande A. Casualties of war--military care for the wounded from Iraq and Afghanistan. New England Journal of Medicine. 2004;351(24):2471-5. [pmid: 15590948].
3 Friedemann-Sanchez G, Sayer NA, Pickett T. Provider perspectives on rehabilitation of patients with polytrauma. Archives of Physical Medicine and Rehabilitation. 2008;89(1):171-178. [pmid: 18164350].
4 Warden D. Military TBI during the Iraq and Afghanistan wars. Journal of Head Trauma Rehabilitation. 2006;21(5):398-402. [pmid: 16983225].
5 Montgomery SP, Swiecki CW, Shriver CD. The evaluation of casualties from Operation Iraqi Freedom on return to the continental United States from March to June 2003. Journal of the American College of Surgeons. 2005;201(1):7-12. discussion 12–3. [pmid: 15978435].
6 Lin DL, Kirk KL, Murphy KP, McHale KA, Doukas WC. Evaluation of orthopaedic injuries in Operation Enduring Freedom. Journal of Orthopaedic Trauma. 2004;18(8 Suppl):S48-53. [pmid: 15472566].
7 Okie S. Traumatic brain injury in the war zone. New England Journal of Medicine. 2005;352(20):2043-7. [pmid: 15901856].
8 Scott SG, Belanger HG, Vanderploeg RD, Massengale J, Scholten J. Mechanism-of-injury approach to evaluating patients with blast-related polytrauma. Journal of the American Osteopathic Association. 2006;106(5):265-70. [pmid: 16717367].
9 DePalma RG, Burris DG, Champion HR, Hodgson MJ. Blast injuries. New England Journal of Medicine. 2005;352(13):1335-42. [pmid: 15800229].
10 Okie S. Reconstructing lives--a tale of two soldiers. New England Journal of Medicine. 2006;355(25):2609-15. [pmid: 17182985].
11 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. 2001;20(3 Suppl):21-35. [pmid: 11306229].
12 Atkins D, Best D, Briss PA, Eccles M, Falck-Ytter Y, Flottorp S, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
13 Nicholson K. Pain, cognition and traumatic brain injury. NeuroRehabilitation. 2000;14(2):95-103. [pmid: 11455072].
14 Nicholson K, Martelli MF, Zasler ND. Does pain confound interpretation of neuropsychological test results?. Neurorehabilitation. 2001;16(4):225-30. [pmid: 11790908].
15 Hart RP, Martelli MF, Zasler ND. Chronic pain and neuropsychological functioning. Neuropsychology Review. 2000;10(3):131-49. [pmid: 10983898].
16 Grace GM, Nielson WR, Hopkins M, Berg MA. Concentration and memory deficits in patients with fibromyalgia syndrome. J Clin Exp Neuropsychol. 1999;21(4):477-87. [pmid: 10550807].
17 Kewman DG, Vaishampayan N, Zald D, Han B. Cognitive impairment in musculoskeletal pain patients. International Journal of Psychiatry in Medicine. 1991;21(3):253-62. [pmid: 1955277].
18 Veiel HO. A preliminary profile of neuropsychological deficits associated with major depression. J Clin Exp Neuropsychol. 1997;19(4):587-603. [pmid: 9342691].
19 Eccleston C, Crombez G, Aldrich S, Stannard C. Attention and somatic awareness in chronic pain. Pain. 1997;72(1–2):209-15. [pmid: 9272805].
20 Pilcher JJ, Huffcutt AI. Effects of sleep deprivation on performance: a meta-analysis. Sleep. 1996;19(4):318-26. [pmid: 8776790].
21 Helfand M, Freeman M. Assessment and management of acute pain in adult medical inpatients: A systematic review. Washington, DC. 2007.
22 Herr K, Bjoro K, Decker S. Tools for assessment of pain in nonverbal older adults with dementia: a state-of-the-science review. Journal of Pain & Symptom Management. 2006;31(2):170-92. [pmid: 16488350].
23 van Herk R, van Dijk M, Baar FP, Tibboel D, de Wit R. Observation scales for pain assessment in older adults with cognitive impairments or communication difficulties. Nurs Res. 2007;56(1):34-43. [pmid: 17179872].
24 Zwakhalen SMG, Hamers JPH, Abu-Saad HH, Berger MPF. Pain in elderly people with severe dementia: a systematic review of behavioural pain assessment tools. BMC Geriatrics. 2006;6:3. [pmid: 16441889].
25 Stolee P, Hillier LM, Esbaugh J, Bol N, McKellar L, Gauthier N. Instruments for the assessment of pain in older persons with cognitive impairment. Journal of the American Geriatrics Society. 2005;53(2):319-26. [pmid: 15673359].
26 Hadjistavropoulos T, Herr K, Turk DC, Fine PG, Dworkin RHP, Helme RM PhD [P], et al. An Interdisciplinary Expert Consensus Statement on Assessment of Pain in Older Persons. Clinical Journal of Pain. 2007;23(Supplement 1):S1-43. [pmid: 17179836].
27 Fuchs-Lacelle S, Hadjistavropoulos T. Development and preliminary validation of the pain assessment checklist for seniors with limited ability to communicate (PACSLAC). Pain Management Nursing. 2004;5(1):37-49. [pmid: 14999652].
28 Warden V, Hurley AC, Volicer L. Development and psychometric evaluation of the Pain Assessment in Advanced Dementia (PAINAD) scale. J Am Med Dir Assoc. 2003;4(1):9-15. [pmid: 12807591].
29 Parmelee P. Pain complaints and cognitive status among elderly institution residents. Journal of the American Geriatrics Society. 1993;41(5):517-522. [pmid: 8486885].
30 Pautex S, Michon A, Guedira M, Emond H, Le Lous P, Samaras D, et al. Pain in severe dementia: self-assessment or observational scales?. Journal of the American Geriatrics Society. 2006;54(7):1040-5. [pmid: 16866673].
31 Buffum MD, Hutt E, Chang VT, Craine MH, Snow AL. Cognitive impairment and pain management: Review of issues and challenges. Journal of Rehabilitation Research & Development. 2007;44(2):315-30. [pmid: 17551882].
32 Assessing Pain in the Patient with Impaired Communication: A Consensus Statement from the VHA National Pain Management Strategy Coordinating Committee. Affairs V, editor. 2004.
33 Pezzin LE, Dillingham TR, MacKenzie EJ. Rehabilitation and the long-term outcomes of persons with trauma-related amputations. Archives of Physical Medicine & Rehabilitation. 2000;81(3):292-300. [pmid: 10724073].
34 Hassantash SA, Afrakhteh M, Maier RV. Causalgia: a meta-analysis of the literature. Archives of Surgery. 2003;138(11):1226-31. [pmid: 14609871].
35 Andy OJ. Post concussion syndrome: brainstem seizures, a case report. Clinical Electroencephalography. 1989;20(1):24-34. [pmid: 2784362].
36 Donnellan CP. Acupuncture for central pain affecting the ribcage following traumatic brain injury and rib fractures--a case report. Acupuncture in Medicine. 2006;24(3):129-33. [pmid: 17013360].
37 Bergfeldt U, Borg K, Kullander K, Julin P. Focal spasticity therapy with botulinum toxin: effects on function, activities of daily living and pain in 100 adult patients. Journal of Rehabilitation Medicine. 2006;38(3):166-71. [pmid: 16702083].
38 Ribbers GM, Stam HJ. Complex regional pain syndrome type I treated with topical capsaicin: a case report. Archives of Physical Medicine and Rehabilitation. 2001;82(6):851-852. [pmid: 11387594].
39 Zachariah SB, Borges EF, Varghese R, Cruz AR, Ross GS. Positive response to oral divalproex sodium (Depakote) in patients with spasticity and pain. American Journal of the Medical Sciences. 1994;308(1):38-40. [pmid: 8010336].
40 Adeloye A. Clinical trial of fluphenazine in the post-concussional syndrome. Practitioner. 1971;206(234):517-9. [pmid: 4930720].
41 Childers MK, Holland D. Psychomotor agitation following gabapentin use in brain injury. Brain Injury. 1997;11(7):537-40. [pmid: 9210989].
42 Batten SV, Pollack SJ. Integrative outpatient treatment for returning service members. J Clin Psychol. 2008;64(8):928-39. [pmid: 18561182].
43 Wardell DW, Rintala DH, Duan Z, Tan G. A pilot study of healing touch and progressive relaxation for chronic neuropathic pain in persons with spinal cord injury. Journal of Holistic Nursing. 2006;24(4):231-40. discussion 241–4. [pmid: 17098874].
44 Jang SH, Shin SW, Ahn SH, Cho IH, Kim SH. Radiation therapy for heterotopic ossification in a patient with traumatic brain injury. Yonsei Medical Journal. 2000;41(4):536-9. [pmid: 10992819].
45 Denys P, Azouvi P, Denormandie P, Samuel C, Patel A, Bussel B. Late cognitive and behavioural improvement following treatment of disabling orthopaedic complications of a severe closed head injury. Brain Injury. 1996;10(2):149-53. [pmid: 8696316].
46 Concalves J, Garcia-March G, Sanchez-Ledesma MJ, Onzain I, Broseta J. Management of intractable spasticity of supraspinal origin by chronic cervical intrathecal infusion of baclofen. Stereotactic & Functional Neurosurgery. 1994;62(1–4):108-12. [pmid: 7631054].
47 Broseta J, Garcia-March G, Sanchez-Ledesma MJ, Anaya J, Silva I. Chronic intrathecal baclofen administration in severe spasticity. Stereotactic & Functional Neurosurgery. 1990:54-55. 147. 53.
48 Becker R, Alberti O, Bauer BL. Continuous intrathecal baclofen infusion in severe spasticity after traumatic or hypoxic brain injury. Journal of Neurology. 1997;244(3):160-6. [pmid: 9050956].
49 Francisco GE, Hu MM, Boake C, Ivanhoe CB. Efficacy of early use of intrathecal baclofen therapy for treating spastic hypertonia due to acquired brain injury. Brain Injury. 2005;19(5):359-64. [pmid: 16094783].
50 Francisco GE, Latorre JM, Ivanhoe CB. Intrathecal baclofen therapy for spastic hypertonia in chronic traumatic brain injury. Brain Injury. 2007;21(3):335-8. [pmid: 17453762].
51 Son BC, Lee SW, Choi ES, Sung JH, Hong JT. Motor cortex stimulation for central pain following a traumatic brain injury. Pain. 2006;123(1–2):210-6. [pmid: 16616421].
52 Gallagher R, Drance E, Higginbotham S. Finding the person behind the pain: chronic pain management in a patient with traumatic brain injury. Journal of the American Medical Directors Association. 2006;7(7):432-4. [pmid: 16979087].
53 Chen KW, Turner FD. A case study of simultaneous recovery from multiple physical symptoms with medical qigong therapy. Journal of Alternative & Complementary Medicine. 2004;10(1):159-62.
54 Shah RV, Racz GB. Long-term relief of posttraumatic headache by sphenopalatine ganglion pulsed radiofrequency lesioning: a case report. Archives of Physical Medicine & Rehabilitation. 2004;85(6):1013-6. [pmid: 15179659].
55 Verdolin MH, Stedje-Larsen ET, Hickey AH. Ten consecutive cases of complex regional pain syndrome of less than 12 months duration in active duty United States military personnel treated with spinal cord stimulation. Anesth Analg. 2007;104(6):1557-60. table of contents. [pmid: 17513657].
56 Leyton N. Post-concussional migraine: a successful response to treatment. The Medical press. 1951;226(2):46-47. [pmid: 14852250].
57 Hoge CW, McGurk D, Thomas JL, Cox AL, Engel CC, Castro CA. Mild traumatic brain injury in U.S. Soldiers returning from Iraq. N Engl J Med. 2008;358(5):453-63. [pmid: 18234750].
58 Warden DL, Ryan LM, Helmick KM, Schwab K, French L, Lu W, et al. War Neurotrauma: the Defense and Veterans Brain Injury Center (DVBIC) Experience at Walter Reed Army Medical Center (WRAMC). The 23rd Annual National Neurotrauma Society Symposium. 2005 November 10–11, 2005. Washington, DC. 2005.
59 Cernak IMDP, Savic JMDP, Ignjatovic DMDP, Jevtic MMDP. Blast Injury from Explosive Munitions. J Trauma. 1999;47(1):96-103. [pmid: 10421194].
60 Cave KM, Cornish EM, Chandler DW. Blast injury of the ear: clinical update from the global war on terror. Military Medicine. 2007;172(7):726-30. [pmid: 17691685].
61 Taher AA, Johns RM. Mandibular joint dysfunction otalgia caused by a bomb explosion wave. Journal of Craniofacial Surgery. 1992;3(4):223-5. [pmid: 1298426].
62 Lew HL, Lin P-H, Fuh J-L, Wang S-J, Clark DJ, Walker WC. Characteristics and treatment of headache after traumatic brain injury: a focused review. American Journal of Physical Medicine & Rehabilitation. 2006;85(7):619-27. [pmid: 16788394].
63 Baandrup L, Jensen R. Chronic post-traumatic headache--a clinical analysis in relation to the International Headache Classification 2nd Edition. Cephalalgia. 2005;25(2):132-8. [pmid: 15658950].
64 Bekkelund SI, Salvesen R. Prevalence of head trauma in patients with difficult headache: the North Norway Headache Study. Headache. 2003;43(1):59-62. [pmid: 12864760].
65 Bettucci D, Aguggia M, Bolamperti L, Riccio A, Mutani R. Chronic post-traumatic headache associated with minor cranial trauma: a description of cephalalgic patterns. Italian Journal of Neurological Sciences. 1998;19(1):20-4. [pmid: 10935855].
66 Haas DC. Characteristics of chronic posttraumatic headache. Headache. 2002;42(2):162-3. [pmid: 12005299].
67 Radanov BP, Di Stefano G, Augustiny KF. Symptomatic approach to posttraumatic headache and its possible implications for treatment. European Spine Journal. 2001;10(5):403-7. [pmid: 11718194].
68 Nampiaparampil DE. Prevalence of chronic pain after traumatic brain injury: a systematic review. JAMA. 2008;300(6):711-9. [pmid: 18698069].
69 Schaller WF. After-effects of Head Injury. The Journal of the American Medical Association. 1939;113(20):1779-1785.
70 Walker WC, Seel RT, Curtiss G, Warden DL. Headache after moderate and severe traumatic brain injury: a longitudinal analysis. Archives of Physical Medicine & Rehabilitation. 2005;86(9):1793-800. [pmid: 16181945].
71 Hoffman JM, Pagulayan KF, Zawaideh N, Dikmen S, Temkin N, Bell KR. Understanding pain after traumatic brain injury: impact on community participation. American Journal of Physical Medicine & Rehabilitation. 2007;86(12):962-9. [pmid: 18090437].
72 Bryant RA, Marosszeky JE, Crooks J, Baguley IJ, Gurka JA. Interaction of posttraumatic stress disorder and chronic pain following traumatic brain injury. Journal of Head Trauma Rehabilitation. 1999;14(6):588-94. [pmid: 10671704].
73 Masson F, Maurette P, Salmi LR, Dartigues JF, Vecsey J, Destaillats JM, et al. Prevalence of impairments 5 years after a head injury, and their relationship with disabilities and outcome. Brain Injury. 1996;10(7):487-97. [pmid: 8806009].
74 Hillier SL, Sharpe MH, Metzer J. Outcomes 5 years post-traumatic brain injury (with further reference to neurophysical impairment and disability). Brain Injury. 1997;11(9):661-75. [pmid: 9376834].
75 Guttman E. Postcontusional Headache. Lancet. 1943;1:10-12.
76 Olver JH, Ponsford JL, Curran CA. Outcome following traumatic brain injury: a comparison between 2 and 5 years after injury. Brain Injury. 1996;10(11):841-8. [pmid: 8905161].
77 Cosgrove JL, Vargo M, Reidy ME. A prospective study of peripheral nerve lesions occurring in traumatic brain-injured patients. American Journal of Physical Medicine & Rehabilitation. 1989;68(1):15-7. [pmid: 2917053].
78 Cantor JB, Ashman T, Gordon W, Ginsberg A, Engmann C, Egan M, et al. Fatigue after traumatic brain injury and its impact on participation and quality of life. The Journal of head trauma rehabilitation. 2008;23(1):41-51. [pmid: 18219234].
79 Beetar JT, Guilmette TJ, Sparadeo FR. Sleep and pain complaints in symptomatic traumatic brain injury and neurologic populations. Archives of Physical Medicine & Rehabilitation. 1996;77(12):1298-302. [pmid: 8976315].
80 Sayer NA, Chiros CE, Sigford B, Scott S, Clothier B, Pickett T, et al. Characteristics and rehabilitation outcomes among patients with blast and other injuries sustained during the Global War on Terror. Archives of Physical Medicine and Rehabilitation. 2008;89(1):163-170. [pmid: 18164349].
81 Lahz S, Bryant RA. Incidence of chronic pain following traumatic brain injury. Archives of Physical Medicine & Rehabilitation. 1996;77(9):889-91. [pmid: 8822679].
82 Wilkinson M, Gilchrist E. Post-traumatic headache. Upsala Journal of Medical Sciences - Supplement. 1980;31:48-51. [pmid: 6935860].
83 Leung J, Moseley A, Fereday S, Jones T, Fairbairn T, Wyndham S. The prevalence and characteristics of shoulder pain after traumatic brain injury. Clinical Rehabilitation. 2007;21(2):171-81. [pmid: 17264111].
84 Gellman H, Keenan MA, Stone L, Hardy SE, Waters RL, Stewart C. Reflex sympathetic dystrophy in brain-injured patients. Pain. 1992;51(3):307-11. [pmid: 1491858].
85 Uomoto JM, Esselman PC. Traumatic brain injury and chronic pain: differential types and rates by head injury severity. Archives of Physical Medicine & Rehabilitation. 1993;74(1):61-4. [pmid: 8420522].
86 Yamaguchi M. Incidence of headache and severity of head injury. Headache. 1992;32(9):427-31. [pmid: 1446984].
87 Brenner C. Post-traumatic headache. J Neurosurgery. 1944;1:379-391.
88 Russell WR. Cerebral involvement in head injury: a study based on the examination of two hundred cases. Brain. 1932;55:549-562.
89 MacKenzie EJ, McCarthy ML, Ditunno JF, Forrester-Staz C, Gruen GS, Marion DW, et al. Using the SF-36 for characterizing outcome after multiple trauma involving head injury. J Trauma. 2002;52(3):527-34. [pmid: 11901330].
90 Ulvik A, Kvale R, Wentzel-Larsen T, Flaatten H. Quality of life 2–7 years after major trauma. Acta Anaesthesiologica Scandinavica. 2008;52(2):195-201. [pmid: 18005377].
91 Couch JR, Bearss C. Chronic daily headache in the posttrauma syndrome: relation to extent of head injury. Headache. 2001;41(6):559-64. [pmid: 11437891].
92 Kay DW, Kerr TA, Lassman LP. Brain trauma and the postconcussional syndrome. Lancet. 1971;2(7733):1052-5. [pmid: 4106910].
93 Tsushima WT, Tsushima VG. Relation between headaches and neuropsychological functioning among head injury patients. Headache. 1993;33(3):139-42. [pmid: 8486511].
94 Bay E, Donders J. Risk factors for depressive symptoms after mild-to-moderate traumatic brain injury. Brain Inj. 2008;22(3):233-41. [pmid: 18297595].
95 Bushnik T, Englander J, Katznelson L. Fatigue after TBI: association with neuroendocrine abnormalities. Brain Inj. 2007;21(6):559-66. [pmid: 17577706].
96 Ouellet M-C, Beaulieu-Bonneau S, Morin CM. Insomnia in patients with traumatic brain injury: frequency, characteristics, and risk factors. Journal of Head Trauma Rehabilitation. 2006;21(3):199-212. [pmid: 16717498].
97 Fichtenberg NL, Millis SR, Mann NR, Zafonte RD, Millard AE. Factors associated with insomnia among post-acute traumatic brain injury survivors. Brain Injury. 2000;14(7):659-67. [pmid: 10914647].
98 Roganovic Z, Mandic-Gajic G. Pain syndromes after missile-caused peripheral nerve lesions: part 2--treatment. Neurosurgery. 2006;59(6):1238-49. discussion 1249–51. [pmid: 17277686].
99 Roganovic Z, Mandic-Gajic G. Pain syndromes after missile-caused peripheral nerve lesions: part 1--clinical characteristics. Neurosurgery. 2006;59(6):1226-36. discussion 1236–7. [pmid: 17277685].
100 Frink M, Klaus A-K, Kuther G, Probst C, Gosling T, Kobbe P, et al. Long term results of compartment syndrome of the lower limb in polytraumatised patients. Injury. 2007;38(5):607-13. [pmid: 17306263].
101 Dougherty PJ. Transtibial amputees from the Vietnam War. Twenty-eight-year follow-up. Journal of Bone & Joint Surgery - American Volume 2001. 83-A(3):383-9.
102 Dougherty PJ. Long-term follow-up study of bilateral above-the-knee amputees from the Vietnam War. Journal of Bone & Joint Surgery - American Volume. 1999;81(10):1384-90.
103 Lacoux PA, Crombie IK, Macrae WA. Pain in traumatic upper limb amputees in Sierra Leone. Pain. 2002;99(1–2):309-12. [pmid: 12237209].
104 Millstein S, Bain D, Hunter GA. A review of employment patterns of industrial amputees--factors influencing rehabilitation. Prosthetics & Orthotics International. 1985;9(2):69-78. [pmid: 4047922].
105 Zelle BA, Brown SR, Panzica M, Lohse R, Sittaro NA, Krettek C, et al. The impact of injuries below the knee joint on the long-term functional outcome following polytrauma. Injury. 2005;36(1):169-77. [pmid: 15589937].
106 Tran T, Thordarson D. Functional outcome of multiply injured patients with associated foot injury. Foot & Ankle International. 2002;23(4):340-3. [pmid: 11991481].
107 Turchin DC, Schemitsch EH, McKee MD, Waddell JP. Do foot injuries significantly affect the functional outcome of multiply injured patients?. Journal of Orthopaedic Trauma. 1999;13(1):1-4. [pmid: 9892116].
108 Urquhart DM, Williamson OD, Gabbe BJ, Cicuttini FM, Cameron PA, Richardson MD, et al. Outcomes of patients with orthopaedic trauma admitted to level 1 trauma centres. ANZ Journal of Surgery. 2006;76(7):600-6. [pmid: 16813626].
109 Brenneman FD, Katyal D, Boulanger BR, Tile M, Redelmeier DA. Long-term outcomes in open pelvic fractures. J Trauma. 1997;42(5):773-7. [pmid: 9191654].
110 Hebert JS, Burnham RS. The effect of polytrauma in persons with traumatic spine injury. A prospective database of spine fractures. Spine. 2000;25(1):55-60. [pmid: 10647161].
111 Vles WJ, Steyerberg EW, Essink-Bot ML, van Beeck EF, Meeuwis JD, Leenen LP. Prevalence and determinants of disabilities and return to work after major trauma. J Trauma. 2005;58(1):126-35. [pmid: 15674163].
112 Anke AG, Stanghelle JK, Finset A, Roaldsen KS, Pillgram-Larsen J, Fugl-Meyer AR. Long-term prevalence of impairments and disabilities after multiple trauma. J Trauma. 1997;42(1):54-61. [pmid: 9003258].
113 Soberg HL, Bautz-Holter E, Roise O, Finset A. Long-term multidimensional functional consequences of severe multiple injuries two years after trauma: a prospective longitudinal cohort study. J Trauma. 2007;62(2):461-70. [pmid: 17297337].
114 Holtslag HR, van Beeck EF, Lindeman E, Leenen LPH. Determinants of long-term functional consequences after major trauma. J Trauma. 2007;62(4):919-27. [pmid: 17426549].
115 Meerding WJ, Looman CW, Essink-Bot ML, Toet H, Mulder S, van Beeck EF. Distribution and determinants of health and work status in a comprehensive population of injury patients. J Trauma. 2004;56(1):150-61. [pmid: 14749582].
116 Mkandawire NC, Boot DA, Braithwaite IJ, Patterson M. Musculoskeletal recovery 5 years after severe injury: long term problems are common. Injury. 2002;33(2):111-5. [pmid: 11890911].
117 Dimopoulou I, Anthi A, Mastora Z, Theodorakopoulou M, Konstandinidis A, Evangelou E, et al. Health-related quality of life and disability in survivors of multiple trauma one year after intensive care unit discharge. American Journal of Physical Medicine & Rehabilitation. 2004;83(3):171-6. [pmid: 15043350].
118 Brenneman FD, Redelmeier DA, Boulanger BR, McLellan BA, Culhane JP. Long-term outcomes in blunt trauma: who goes back to work?. J Trauma. 1997;42(5):778-81. [pmid: 9191655].
119 MacKenzie EJ, Morris JA Jr, Jurkovich GJ, Yasui Y, Cushing BM, Burgess AR, et al. Return to work following injury: the role of economic, social, and job-related factors. Am J Public Health. 1998;88(11):1630-7. [pmid: 9807528].
120 Stalp M, Koch C, Ruchholtz S, Regel G, Panzica M, Krettek C, et al. Standardized outcome evaluation after blunt multiple injuries by scoring systems: a clinical follow-up investigation 2 years after injury. J Trauma. 2002;52(6):1160-8. [pmid: 12045647].
121 Lippert-Gruner M, Maegele M, Haverkamp H, Klug N, Wedekind C. Health-related quality of life during the first year after severe brain trauma with and without polytrauma. Brain Inj. 2007;21(5):451-5. [pmid: 17522984].
122 Fitzharris M, Fildes B, Charlton J, Kossmann T. General health status and functional disability following injury in traffic crashes. Traffic Injury Prevention. 2007;8(3):309-20. [pmid: 17710722].
123 Taber KH, Warden DL, Hurley RA. Blast-related traumatic brain injury: what is known?. Journal of Neuropsychiatry & Clinical Neurosciences. 2006;18(2):141-5. [pmid: 16720789].
124 Walker W. Concurrent Validity of Four Pain Intensity Scales in persons with Polytrauma and Cognitive Impairment. A research study in progress. Richmond VAMC.
125 Kerns R. Pain Assessment in Polytrauma Rehabilitation Centers (PRCs). A research study in progress. HSR&D QUERI Program RRP07–288. VA Connecticut Healthcare System.
126 Bair M. Evaluation of Stepped CAre for Chronic Pain (ESCAPE). A research study in progress. VA Rehabilitative Research and Development F44371. Indianapolis VAMC.
127 Roy MJ. The ViRTICo Trial: Virtual Reality Therapy & Imaging in Combat Veterans. A research study in progress. Uniformed Services University. Bethesda MD.
128 Gallagher RM. Regional Anesthesia Military Battlefield Pain Outcomes Study. A research study in progress. RR&D Service 951. Philadelphia VAMC.
129 Gironda RJ. Chronic Headache among OEF/OIF Veterans Exposed to Blasts. A research study in progress. Tampa VAMC.
130 Afari N. Headaches in veterans returning from Iraq/Afghanistan: relation to trauma and combat-related injury. A research study in progress. San Diego VAMC.
131 Lawrence VA. Long-term Outcomes in Burned OEF/OIF Veterans (LOBO). A research study in progress. VA HSR&D SDR 07–042. San Antonio VAMC.
132 Brandt C, Haskell S. Women Veterans Cohort Study. A research study in progress. HSR&D DHI 07-065-2. VA Connecticut Healthcare System.
133 Clark ME. Pain and Emotional Disorders in Veterans with and without Polytrauma. A research study in progress. HSR&D SDR-07-047. Tampa VAMC.
134 Storzbach D. Multidiscipline Assessment of Blast Victims for Cognitive Rehabilitation. A research study in progress. VHA RR&D B5060R. Portland VAMC.
135 Siddharthan K. Telerehabilitation of OEF/OIF combat wounded with TBI. A research study in progress. Tampa VAMC.
136 Lew H. Predicting Rehabilitation Costs for VA Patients with Traumatic Brain Injury. A research study in progress. VA Boston HealthCare System.
137 Lew H. Characterization and Care Coordination of Polytrauma Patients. A research study in progress. VA Boston HealthCare System.
138 Helmer D. Pain, mental health, and daily function in OIF/OEF veterans. A research study in progress. Houston VAMC.
139 Lew H. Clinical Characteristics of Patients with Polytrauma and Blast-Related Injuries. A research study in progress. VA Boston HealthCare System.
140 Walker RL. Evaluation of Polytrauma Pain. A research study in progress. Tampa VAMC.
141 Widerstrom-Noga E. Validity and reliability of proton magnetic resonance spectroscopy as a diagnostic and outcome measure in clinical pain trials involving people with spinal cord injury. A research study in progress. Miami VA HCS.
142 Goel A, Phalke U, Cacciola F, Muzumdar D. Atlantoaxial instability and retroodontoid mass--two case reports. Neurologia Medico-Chirurgica. 2004;44(11):603-6. [pmid: 15686182].