# METHODS

## Topic Development

This topic was nominated by Michael Clark, PhD, Clinical Director of the Pain Program, James A. Haley VAMC. The scope and key questions for the review were further refined in consultation with representatives from the VA HSR&D Service, the VA Evidence Synthesis Program, and technical experts in pain, polytrauma, or traumatic brain injury (Robert Kerns, PhD; Nina Sayer, PhD; Marti Buffum DNSc, APRN, BC, CS; Michael Clark, PhD; Henry Lew, MD, PhD; Nancy Carney, PhD; Ron Gironda, PhD; Martin Schreiber, MD).

1. Have reliable and valid measures and assessment tools been developed to measure pain intensity and pain-related functional interference among patients with cognitive deficits due to TBI? Which measures and tools are likely to be most useful in assessing pain in polytrauma patients with cognitive deficits due to TBI?
2. A. Which treatment approaches are most likely to be effective in improving pain outcomes (pain intensity and functional interference) in polytrauma patients? B. Which pain treatment approaches are most likely to enhance overall rehabilitation efforts?
3. A. Does blast-related headache pain differ in terms of phenomenology and treatment from other types of headache pain? B. Which treatments are best for persistent blast-related headache pain?
4. What patient factors are associated with better and worse pain-related clinical outcomes among polytrauma patients? Have interventions been developed to specifically address these factors?
5. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers?

Polytrauma is defined as concurrent injury to two or more body parts or systems resulting in cognitive, physical, psychological or other psychosocial impairments. Combat-related mental conditions co-occurring with injury to at least one other system also constitutes polytrauma.

The scope of this review includes the assessment and treatment in rehabilitation and post-rehabilitation care settings of persistent pain or exacerbations of pain resulting from polytraumatic injuries. We included studies measuring pain-related outcomes, specifically pain intensity and pain-related function or interference, 3 months or more from the date of injury.

The scope of this review excludes the following:

- Short-term (less than 3 months) outcomes following injury. We sought to focus on pain persisting into the rehabilitation phase of treatment or longer, and not battlefield or acute management of polytraumatic injury.
- Unilateral amputation without other concurrent conditions or injuries. Bilateral amputation was considered polytrauma.
- Spinal cord injury without other concurrent conditions or injuries
- Choice of specific surgical strategy or specific procedures for particular orthopedic injuries or perioperative management of traumatic injuries.
- Post-traumatic/post-concussive headache unrelated to blast injury, unless the sample includes patients with moderate or greater TBI.
- Functional outcomes of polytrauma unless pain measures are included as one component of the functional outcome measure or in addition to the functional outcome measure.

Figure 1 illustrates the analytic framework that guided our review and synthesis.

Figure 1 Analytic Framework

## Literature Search Strategy

Two research librarians (Rose Campbell and Andrew Hamilton) independently designed search strategies based on the key questions, and conducted searches in Medline of literature published from 1950 through July 2008. Appendix A provides the search strategies in detail. The results of both searches were combined into a single reference library. Additional articles were identified from reference lists of studies, review articles, editorials, and by consulting experts. We also searched for relevant studies in the following databases: PsychINFO; the PILOTS Database (the VA PTSD bibliographic database); REHABDATA, the bibliographic database of the National Rehabilitation Information Center; the DoD Defense Technical Information Center; and the Cochrane Database of controlled clinical trials. All citations were imported into an electronic database (EndNote X1). We also searched for unpublished and ongoing research studies, as described in the section on Active Research to follow.

## Study Selection

Three researchers (SD, RC, MF) trained in the critical analysis of literature reviewed the titles and abstracts identified from the searches. Full-text articles of potentially relevant abstracts were retrieved for further review. Each article retrieved was reviewed with a brief screening form (see Appendix B) that collected data on the key question to which the article applied, as well as key words or emerging themes. Reference lists from pertinent articles were reviewed to find additional articles for inclusion.

### Study Inclusion Criteria

Eligible articles had English-language abstracts and provided primary data relevant to the key questions. For a study to be eligible for Key Questions 1, 2, 4 and 5, the sample had to have all or a majority of patients with polytrauma, or analyses and findings had to be stratified by whether the patients had polytrauma, such that if a minority of the sample had polytrauma, readers could discern outcomes for the polytrauma group. For purposes of the review, polytrauma was defined as concurrent injury to two or more body parts or systems resulting in cognitive, physical, psychological or other psychosocial impairments. TBI of moderate or greater severity was also considered polytrauma (head injury itself plus associated cognitive sequellae). Combat-related mental conditions co-occurring with injury to at least one other system also constituted polytrauma. This definition is consistent with the VHA Directive 2005-024 describing the policy for the PRCs. Eligible studies examined the assessment and treatment in rehabilitation and post-rehabilitation care settings of persistent pain or exacerbations of pain resulting from polytraumatic injuries.

Eligible study designs included controlled clinical trials, systematic reviews, as well as prospective and retrospective cohort studies, case-control design studies, and qualitative studies using rigorous qualitative research methods. For these types of study designs, we abstracted data as described below. Due to a limited number of studies that included a comparator group, we also considered relevant cross-sectional and case report/case series studies for inclusion for some of the key questions. For these study designs, data were not formally abstracted nor rated for quality of evidence.

### Study Exclusion Criteria

Studies examining battlefield/emergency or assessment and care within 3 months of injury were not included unless they also examined pain outcomes 3 months or more from the date of injury, that is, pain persisting into the rehabilitation phase of treatment or longer. We also did not include studies examining choice of specific surgical strategy, the perioperative management of traumatic injuries (including burn injuries), or use of particular procedures or devices for specific orthopedic injuries. There are numerous case reports and case series describing specific surgical interventions for particular types of wounds; we felt that their inclusion would not yield generalizable information. We excluded studies describing functional outcomes of polytrauma unless a pain measure was included and reported as a component of the functional outcome measure or in addition to the functional outcome measure. Finally, we excluded studies of post-traumatic/post-concussive headache unless the sample included patients with moderate or more severe head injury or included a majority of patients with blast-related head injury. There have been a number of narrative reviews of assessment and treatment of post-traumatic headache among patients with mild-TBI or post-concussive syndrome; we felt that inclusion of these studies was beyond the scope of our key questions.

### Secondary Findings

For key questions 1, 2, 3, and 4, the investigators included additional information (labeled Secondary Findings) from studies that were formally excluded during the search and abstraction process, but which contained information that seemed pertinent to the key questions and which we felt may be of interest to readers. This additional information does not reflect results of a comprehensive, systematic literature search on the specific secondary findings topics; rather it reflects information derived from manuscripts identified during our main search process.

## Data Abstraction

We abstracted the following data from included studies: study design, setting, objectives, eligibility criteria, sample size, intervention or exposure of interest, comparator intervention or control group, outcomes measured, timing of outcome assessment, years of enrollment/observation, duration of follow-up, demographics, potential confounders considered, results, and conclusions.

## Quality Assessment

We assessed the quality of studies when applicable, using criteria developed by the US Preventive Services Task Force(11) for rating randomized controlled trials, cohort studies, and case control studies (Appendix C). We did not rate the quality of cross-sectional studies, case reports, or case series.

## Data Synthesis

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question, intervention, or clinical condition, as appropriate. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each key question or clinical topic, and drew conclusions based on qualitative synthesis of the findings.

## Rating the body of evidence

We assessed the overall quality of evidence for outcomes using a method developed by the Grading of Recommendations, Assessment, Development, and Evaluation (GRADE) Working Group, which classified the grade of evidence across outcomes according to the following criteria:(12)

[underlined: High] = Further research is very unlikely to change our confidence on the estimate of effect.

[underlined: Moderate] = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.

[underlined: Low] = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

[underlined: Very Low] = Any estimate of effect is very uncertain.

The GRADE Working Group also suggests using the following scheme for assigning the “grade” or strength of evidence:

Criteria for assigning GRADE of evidence
Type of evidence
Randomized trial = high
Observational study = low
Any other evidence = very low
Decrease GRADE if:; - Serious (−1) or very serious (−2) limitation to study quality; - Important inconsistency (−1); - Some (−1) or major (−2) uncertainty about directness; - Imprecise or sparse data (−1); - High probability of reporting bias (−1)
Increase GRADE if:; - Strong evidence of association-significant relative risk of >2 (<0.5) based on consistent evidence from two or more observational studies, with no plausible confounders (+1); - Very strong evidence of association-significant relative risk of >5 (<0.2) based on direct evidence with no major threats to validity (+2); - Evidence of a dose response gradient (+1); - All plausible confounders would have reduced the effect (+1)

## Active Research

In addition to conducting a formal evidence synthesis, we conducted a survey to identify and describe current or planned research that is addressing or will address the key questions. Specific objectives were to 1) describe the data that are being collected that will help to address the key questions, 2) propose actions needed to address the key questions above within a reasonable time frame.

To identify ongoing or planned research relating to key questions, we began by sending email communications inquiring about active or planned research to groups and individuals. The groups and individuals sent initial email communications were:

- Investigators working in the areas of pain, polytrauma or TBI that were known to the Evidence Synthesis investigators or, as indicated from recent published manuscripts, are currently likely to be conducting studies in these areas. We specifically sent initial emails to several DOD researchers thought to be studying patients with polytraumatic injuries.
- Chairs of active VA workgroups, the Assessing pain in TBI workgroup (Buffum), VA Polytrauma Centers Workgroup (Clark), and the TBI QUERI Workgroup (Sayer). The PI of the current evidence synthesis project is a member of the VHA Pain Research Workgroup and sent an email communication directly to all members of this workgroup. We also discussed this evidence synthesis project with chairs and members of these workgroups.
- Investigators of projects on polytrauma and pain identified from queries and hand-searches of several VA and non-VA website databases: (National Institutes of Health Clinical Trials data base (http:www.clinicaltrials.gov), the Computer Retrieval of Information on Scientific Projects (CRISP) database (http://crisp.cit.nih.gov/), the Meta-Register of Current Controlled Trials (http://www.controlled-trials.com/mrct/), and the VA HSR&D website (http://www.hsrd.research.va.gov/research/default.cfm).
- Each of the five HSR&D VA portfolio managers.

Email communications described our goals and the task, and asked respondents to also identify other investigators who might be working in these areas (snowball approach). Initial email messages were sent at the end of January 2008; email messages to newly identified investigators and follow-up communications occurred continuously until August 28, 2008.

## PEER REVIEW

A draft version of this report was sent to the technical advisory panel and additional peer reviewers. Their comments and our responses are shown in Appendix D.