# FUTURE RESEARCH RECOMMENDATIONS

In order to highlight gaps between the key questions and information available from the literature and information to become available based on current research, Table 4 depicts the results of the literature review of studies that have been published to date, the types of studies necessary to address the key questions, and the research we identified that is currently being done to address the key questions.

Table 4 Summary of Literature Review Findings and Identified Ongoing Research

Key Question or Subquestion | Results of Literature Review | Types of studies needed to answer question | Identified ongoing research
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Qualitative research in rehabilitation patients with polytrauma | - Qualitative/quantitative study of clinicians from PRCs regarding pain education & assessment tools(125)
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Prospective observational study of reliability and validity of instruments in rehabilitation patients with polytrauma | - Prospective randomized study comparing validity of 4 pain scales in TBI patients(124)
2a. Which treatments improve pain outcomes in polytrauma patients? 2b. Which pain treatment approaches enhance overall rehabilitation efforts? | - Case series and case reports of various pain treatments.; - Little to no information on use of opioids or integrated care approaches | Exploratory research: feasibility of treatment modalities in case series | - Case series pilot of cognitive behavioral intervention for blast headache(129); - Clinical trial of Virtual reality therapy for TBI (pain secondary outcome)(127)
2a. Which treatments improve pain outcomes in polytrauma patients? 2b. Which pain treatment approaches enhance overall rehabilitation efforts? | - Case series and case reports of various pain treatments.; - Little to no information on use of opioids or integrated care approaches | Effectiveness research: Controlled comparisons of different treatment strategies in patients with polytrauma before or at inception of rehabilitation | - RCT of stepped care in OIF/OEF veterans with severe chronic musculoskeletal pain(126); - Prospective cohort study of outcomes of regional anesthesia(128)
3a. Does blast-related headache pain differ from other types of headache pain? | - None.; - Headache and auditory deficits are common in patients exposed to blast | Prospective, observational studies to determine whether features of injuries, including exposure to blasts, are associated with a different clinical course and outcome. | - Case series pilot of cognitive behavioral intervention for blast headache(129)
3b. Which treatments are best for persistent blast-related headache pain? | None. | Exploratory research: feasibility of treatment modalities in case series | - Case series on brief cognitive-behavioral headache management treatment (BCBHMT) of blast-TBI(129)
3b. Which treatments are best for persistent blast-related headache pain? | None. | Effectiveness research: Controlled comparisons of different treatment strategies in patients with blast-related headache | No identified studies using this design
4a. What patient factors are associated with better and worse (pain-related) clinical outcomes among polytrauma patients? | - Cohort, case control, and cross-sectional studies.; - Injury characteristics, insomnia, fatigue, and psychosocial factors are associated with pain-related outcomes (Grade: Low) | Prospective observational study of factors associated with pain-related outcomes among polytrauma patients. | - 6 prospective cohort studies examining various (including pain-related) outcomes).(128, 131–135); - 1 retrospective cohort study(136) and 5 cross-sectional studies.(130, 137–140)
4a. What patient factors are associated with better and worse (pain-related) clinical outcomes among polytrauma patients? | - Cohort, case control, and cross-sectional studies.; - Injury characteristics, insomnia, fatigue, and psychosocial factors are associated with pain-related outcomes (Grade: Low) | Effectiveness research: Controlled comparisons of different treatment strategies in patients with and without certain characteristics | - Clinical trial of Virtual reality therapy in TBI patients (pain secondary outcome)(127); - RCT of stepped care in OIF/OEF veterans with severe chronic musculoskeletal pain(126)
4b. Have interventions been developed to specifically address these factors? | None. | Exploratory research: feasibility of treatment modalities in case series | No identified studies using this design
4b. Have interventions been developed to specifically address these factors? | None. | Effectiveness research: Controlled comparisons of treatment strategies in patients with comorbid conditions | No identified studies using this design
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? | One qualitative study of interviews with providers. | Qualitative research in rehabilitation patients with polytrauma | - Qualitative/quantitative study of clinicians from PRCs regarding pain education & assessment tools (125)
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? | One qualitative study of interviews with providers. | Prospective observational study of provider and systems factors associated with pain-related outcomes in polytrauma patients. | No identified studies using this design
5b. Have interventions been developed to effectively address these barriers? | None. | Exploratory research: feasibility of treatment modalities in case series | No identified studies using this design
5b. Have interventions been developed to effectively address these barriers? | None. | Effectiveness research: Controlled comparisons of treatment strategies in patients with polytrauma | No identified studies using this design

Table 5 lists potential study topics and designs as suggested by the investigators and expert reviewers based on the above identified information gaps, and includes their cumulative ratings of the priority of conducting particular studies. Raters were asked to review the research topics and assign them high, medium or low priority, the most important criterion being to achieve the highest possible impact on patient care in the VHA. In rating the suggestions for future research, raters were also asked to consider: 1) the degree to which the proposed research will address information gaps identified in the systematic review, 2) the quantity and quality of the research completed so far including systematic reviews; 3) research currently planned or in progress; 4) the feasibility and timeframe that would be necessary to complete the proposed research; 5) existing barriers that have prevented this research from being undertaken before, and 6) the pros and cons of different research methods that might be appropriate for each research question. Table 5 presents the mean priority ranking for each research topic, based on input from 11 reviewers. Because these are preliminary rankings, a panel or other mechanism to achieve consensus is needed to refine and finalize the recommendations for future research.

Table 5 Future Research Topics/Designs – Ratings of Priority

Key Question or Subquestion | Results of Literature Review | Future Research Topic Suggestions | Median rank 1, 2, or 3 1 = most important | Interquartile range
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Quantitative measurement study of reliability and validity of existing pain assessment tools among patients with varying levels of communicativeness and brain injury. | 1 | 1, 2
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Examine the discriminant validity of tools for distinguishing pain from other forms of distress and impairment (e.g., restlessness, PTSD symptoms) | 1 | 1, 2
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Examine the validity of assessment tools in the context of a clinical trial of an intervention for a specific pain condition. For example, in trial of opioids for patients with multiple orthopedic injuries and TBI, use tool to measure changes in pain over time. | 2 | 1, 2
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Examine utility, reliability and validity of CPRS Pain assessment modules being used in VA PRCs for assessment of non-communicative patients with pain. | 2 | 1, 3
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Qualitative study to identify pain behaviors in different cognitively impaired TBI states. From this information, develop and test new tool or modify existing tools to match severity and type of cognitive impairment. | 2 | 1, 3
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI or polytrauma. | Qualitative/quantitative research using partnership with family (and staff) to identify key pain behaviors. Develop or modify tool to incorporate information from patient, caregivers, and empiric trials of analgesics (i.e., guideline recommended approaches). | 2 | 2, 3
2a. Which treatments improve pain outcomes in polytrauma pts? 2b. Which pain treatment approaches enhance overall rehab. efforts? | - Primarily case series and case reports of various pain treatments.; - Little to no information on use of opioids or integrated care approaches. | Trials of non-pharmacological interventions of varying treatment intensity, including psychological interventions and telephone-based interventions. | 1 | 1, 2
2a. Which treatments improve pain outcomes in polytrauma pts? 2b. Which pain treatment approaches enhance overall rehab. efforts? | - Primarily case series and case reports of various pain treatments.; - Little to no information on use of opioids or integrated care approaches. | RCTs of integrated treatment approaches including comprehensive interdisciplinary rehab., collaborative care, and treatment involving family members. | 1 | 1, 2
2a. Which treatments improve pain outcomes in polytrauma pts? 2b. Which pain treatment approaches enhance overall rehab. efforts? | - Primarily case series and case reports of various pain treatments.; - Little to no information on use of opioids or integrated care approaches. | Compare treatments for common specific core conditions (e.g., TBI; PTSD; Pain) to integrated treatment of these core overlapping symptoms. | 1 | 1, 2
2a. Which treatments improve pain outcomes in polytrauma pts? 2b. Which pain treatment approaches enhance overall rehab. efforts? | - Primarily case series and case reports of various pain treatments.; - Little to no information on use of opioids or integrated care approaches. | Systematic prospective observation methods and single case experimental designs with replication to study the relationship between pain control and rehabilitation outcomes. | 2 | 2, 3
3a. Does blast-related headache pain differ from other types of headache pain? | - None.; - Headache and auditory deficits are common in patients exposed to blast. | Cross sectional study describing and comparing characteristics of veterans with headache presumed to be blast-related to veterans with headache not known to be blast-related. | 2 | 1, 2
3a. Does blast-related headache pain differ from other types of headache pain? | - None.; - Headache and auditory deficits are common in patients exposed to blast. | Prospective observational cohort study comparing outcomes of veterans with blast- related headache to those without blast-related headache | 2 | 1, 2
3a. Does blast-related headache pain differ from other types of headache pain? | - None.; - Headache and auditory deficits are common in patients exposed to blast. | Study associations between comorbid psychiatric conditions and headache among patients with blast-headache; compare to patients with non-blast-headache | 2 | 1, 2
3a. Does blast-related headache pain differ from other types of headache pain? | - None.; - Headache and auditory deficits are common in patients exposed to blast. | Perform routine imaging on soldiers exposed to blast to assess for structural abnormalities and correlate with headache symptoms | 2 | 2, 3
3b. Which treatments are best for persistent blast- related headache pain? | None. | Trials of pharmacologic and non-pharmacologic treatments, including patients with blast-related headache in one arm of the trial. Non-pharmacologic interventions to test include cognitive behavioral treatment, hypnosis, relaxation training, and biofeedback. | 1 | 1, 1
4a. What patient factors are associated with pain-related outcomes in polytrauma patients? Have interventions been developed to specifically address these factors? (see 2. above) | Some evidence that injury characteristics, insomnia, fatigue, and psychosocial factors are associated with pain-related outcomes | Prospective cohort study measuring pain outcomes over time. Measuring contributions of patient characteristics and comorbid conditions, while adjusting for injury characteristics including multiplicity of injury, pain type, and location. | 1 | 1, 2
4a. What patient factors are associated with pain-related outcomes in polytrauma patients? Have interventions been developed to specifically address these factors? (see 2. above) | Some evidence that injury characteristics, insomnia, fatigue, and psychosocial factors are associated with pain-related outcomes | Prospective cohort study examining relationships between pain, PTSD, and TBI, and pain-related outcomes | 1 | 1, 2
4a. What patient factors are associated with pain-related outcomes in polytrauma patients? Have interventions been developed to specifically address these factors? (see 2. above) | Some evidence that injury characteristics, insomnia, fatigue, and psychosocial factors are associated with pain-related outcomes | Collaborate with DOD to collect or obtain existing pre-deployment DOD survey data to adjust for baseline characteristics prior to injuries in prospective or retrospective cohort studies. | 2 | 2, 2
4a. What patient factors are associated with pain-related outcomes in polytrauma patients? Have interventions been developed to specifically address these factors? (see 2. above) | Some evidence that injury characteristics, insomnia, fatigue, and psychosocial factors are associated with pain-related outcomes | Use data obtained in collaboration with DOD and/or from Landsthuhl Regional Medical Center to identify long-term effects of battlefield, acute-phase, or early rehab. treatment. | 2 | 2, 2
4a. What patient factors are associated with pain-related outcomes in polytrauma patients? Have interventions been developed to specifically address these factors? (see 2. above) | Some evidence that injury characteristics, insomnia, fatigue, and psychosocial factors are associated with pain-related outcomes | Evaluate contribution of partnership with family and other social variables to pain- related outcomes in polytrauma patients. | 2 | 2, 3
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers? | One qualitative study of interviews with providers. | Establish treatment guidelines for pain in polytrauma based on expert opinion. Disseminate and measure impact of guidelines on care. | 1 | 1, 2
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers? | One qualitative study of interviews with providers. | Evaluate patient perceptions of provider and systems barriers, and the impact of efforts to mitigate those barriers. | 2 | 1, 2
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers? | One qualitative study of interviews with providers. | Evaluate implementation of CPRS pain assessment tools in PRCs. Refine tools and reevaluate. | 2 | 1, 2
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers? | One qualitative study of interviews with providers. | Couple evaluation of site-specific organizational factors with multi-site prospective observational study of patient pain-related outcomes. Identify associations between organizational factors and patient outcomes. | 2 | 1, 2
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers? | One qualitative study of interviews with providers. | Identify adaptations PRCs are making to accommodate diversity among polytrauma patients with pain. | 2 | 2, 3
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers? | One qualitative study of interviews with providers. | Measure the impact of polytrauma pain education on provider behavior. | 2 | 2, 3
5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to effectively address these barriers? | One qualitative study of interviews with providers. | Formative evaluation of implementation of guidelines and education and impact on treatment processes in PRCs. | 2 | 2, 3

We also note the following considerations for conducting and funding research in this area:

- Substantial heterogeneity in the causes and types of polytraumatic injuries, as well as the dynamic nature of recovery from injuries, create challenges for defining and comparing distinct patient populations in research studies, as well as for developing and testing generalizable interventions. In future research it is critical that investigators comprehensively describe polytrauma study samples, settings, recruitment methods, and measurements.
- Due to the level of heterogeneity in the causes and types of polytraumatic injuries, interventions that have the potential to apply, and that are able to be tested among patients with a wide-spectrum of injury patterns may be especially desirable.
- Pilot studies of interventions may be especially helpful to determine feasibility of treatment approaches in the polytrauma patient population before proceeding to larger-scale randomized clinical trials. Enhancement of funding mechanisms that facilitate such pilot work is desirable.
- Battlefield, acute-phase, or early rehabilitation pain interventions may have an important impact on subsequent pain-related outcomes. The DOD may obtain follow-up survey data that could be used or augmented to conduct pain outcome research. Mechanisms that foster improved DOD/VA collaborations including additional data collection may highly desirable. Establishment of a joint DOD-VA pain workgroup might facilitate such collaboration.