# CONCLUSIONS

Table 3 Summary of Systematic Evidence Review by Key Question

Key Question | Type of Evidence | Quality (GRADE) of Evidence^*^ | Comments
1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI? | No direct evidence on pain assessment tools in TBI | Very Low^*^ | - No particular assessment tool or strategy is known to reliably or validly measure pain intensity or pain-related function in patients with cognitive deficits due to TBI.; - Most patients with mild cognitive impairment due to dementia can understand at least one pain self-assessment measure.; - Pain may interfere with neurocognitive functioning in TBI patients.; - There is no evidence that pain assessment tools for dementia can be reliably applied to persons with cognitive impairment related to TBI
2a. Which treatment approaches are most effective in improving pain outcomes in polytrauma patients? | No direct evidence on effective pain treatment approaches for polytrauma | Very Low | - No rigorous studies have been done assessing potential benefits or risks of opioids in patients with polytrauma.
2b. Which pain treatment approaches enhance overall rehabilitation efforts? | 1 retrospective cohort study | Very Low | - Inpatient rehabilitation may be associated with increased likelihood of return to work and decreased likelihood of reduced hours of work.
3a. Does blast-related headache pain differ from other types of headache pain? | No evidence comparing blast-related headache to other types of headache | Very Low | - It is not known how blast-related headache differs from other types of headache in terms of phenomenology or outcome.; - Headache and auditory deficits are common among patients with blast-injuries.
3b. Which treatments are best for persistent blast-related headache pain? | No evidence on treatment of blast-related headache | --- | - Specific treatments for blast-related related headache pain have not been studied.
4. What patient factors are associated with better and worse clinical outcomes among polytrauma patients? Have interventions been developed to address these factors? | [underlined: Patients with TBI:] 1 systematic review, 10 cohort, 3 case-control, and 11 cross-sectional studies | Very Low | - There are mixed findings regarding the association between severity of TBI and pain.
4. What patient factors are associated with better and worse clinical outcomes among polytrauma patients? Have interventions been developed to address these factors? | [underlined: Patients with TBI:] 1 systematic review, 10 cohort, 3 case-control, and 11 cross-sectional studies | Low^†^ | - Psychological factors, including depression and posttraumatic stress disorder (PTSD), and insomnia and fatigue are associated with pain in TBI patients.
4. What patient factors are associated with better and worse clinical outcomes among polytrauma patients? Have interventions been developed to address these factors? | [underlined: Other patients:] 32 cohort studies, 3 cross-sectional studies | Low | - Specific factors associated with worse pain-related outcomes include: multiple injuries, foot injuries or injuries below the knee joint, and concurrent head injury or cognitive disability.
4. What patient factors are associated with better and worse clinical outcomes among polytrauma patients? Have interventions been developed to address these factors? | [underlined: Other patients:] 32 cohort studies, 3 cross-sectional studies | Very Low | - Factors associated with better outcomes are younger age, higher educational achievement, having a white collar job or higher income.
5. What are unique provider and system barriers to detecting and treating pain among polytrauma patients? Have interventions been developed to address these barriers? | 1 qualitative study of interviews with providers | Very Low | - In qualitative interviews, providers reported that polytrauma patients are very complex to treat, and that the work with this population is very challenging and emotionally taxing. Increasing use of multidisciplinary and concurrent care and consultation from experts may be necessary to provide the care that is needed.

* GRADE: Very low = any estimate of effect is very uncertain.

† GRADE: Low = research is very likely to have an important impact on our confidence in the estimate of effect and may change the effect