# EVIDENCE TABLES

EVIDENCE TABLE 1 Studies on patient factors associated with polytrauma outcomes (Key Question 4)

Author, Year (ref.) | Title | Topic area | Study Design | Sample: All polytrauma patients, majority, or just included? | Aims | Setting | Sample demographics and other characteristics (include average time since injury at study baseline, if applicable) | Inclusion/exclusion criteria | N enrolled, Tx v. controls | Exposure of interest | Control group: Comparator to exposure of interest | Pain-related outcomes measured | Timing of Outcomes | Is pain outcome a [underlined: main outcome] in | Are results stratified or adjusted for polytrauma | Analytic method | Variables adjusted for in analysis or stratification | Results | Quality rating
TBI
Bay, 2008(1) | Risk factors for depressive symptoms after mild-to-moderate traumatic brain injury | TBI | Cross sectional | Included | To determine the extent to which pre-injury psychosocial factors, injury-related variables and post-injury litigation, perceived stress, fatigue, pain and information processing speed contributed to depressive symptoms after traumatic brain injury(TBI) | 8 outpatient rehabilitation cneters in the Midwest | 49% female, 89% white, 77% Glascow Coma Scale (GCS) score 13–15, 45% with CT findings, average 15 months since injury, ave age=38 | Inclusion: 1–36 months from date of injury;hospitalized or seen in ER at time of injury Exclusion: preexisting neurologic/cognitive disorders; severe TBI | 84 | n/a | n/a | McGill Pain Questionaire short form | Single assessment Ave. 15 months post-injury | No | No | multiple regression techniques | Perceived stress, impact of events, litigation status | In a model including perceived stress, impact of events, and litigation stress, pain was significantly associated with depression(partial R(squared)=.07, p=.001) | n/a--cross-sectional
Beetar, 1996(2) | Sleep and Pain Complaints in Symptomatic Traumatic Brain Injury and Neurological Populations | TBI, fatigue, insomnia | Case-contol | Included | To compare the incidence of sleep and pain complaints in symptomatic taumatic brain injury(TBI) (mils vs. moderate/severe) and neurologic populations | Outpatient neuropsychological service at a university affiliated tertiary care center | TBI group: age 36, 68 % male, 24 months post-injury | Cases: patients consectively referred for neuropsychological assessment w. TBI, Controls: referred pts without TBI | 202 TBI pts and 123 non-I TBI pts. | TB | non-TBI | prevalence of pain complaints | Single assessment, av e. 24 months post-injury | No | by TBI severity | bivariate tests | TBI severity | TBI subjects had significantly more insomnia (56.4% vs. 30.9%) and pain complaints (58.9% vs. 22%) than non-TBI subjects(p< .0001). For both subject groups, the presence of pain increased insomnia approximately twofold. | Fair
Brenner, 1944(3) | Post-traumatic Headache | TBI, headache | Cohort--prospective | Majority | Study relationships among manner and degree of head injury, personality factors, compensation, environmental status and headache prevalence and course. | Boston City Hospital | 63% males, 36% Irish, 48% skilled or semi-skilled workers | Inclusion: 200 consecutive patients with head injury admitted to hospital, age 15 to 55. Exclude: unemployed and with chronic alcoholism | 200 enrolled | n/a | none | headache prevalence | During admission, before 2 months, then every 2 months up to 6 to 15 months | Yes | n/a--majority with polytrauma | descriptive only | Head injury severity as measured by duration of post-traumatic amnesia, coma, and disorientation | 69% of patients reported headaches while in hospital and 41% reported headaches after hospitalization. There was no greater prevalence of headache persisting longer than two months among patients with more severe head injuries than patients with milder head injuries. | Fair
Bryant, 1999(4) | Interaction of Posttraumatic Stress Disorder and Chronic Pain following Traumatic Brain Injury | TBI, PSTD | Cohort--prospective | All (severe TBI) | To investigate the association between PTSD and chronic pain in patients who had sustained a severe TBI | Tertiary Care Center, Brain Injury Clinic | 80% male, age not specified | Inclusion: admitted to brain injury rehab with severe TBI | 96 | PTSD with TBI | non PTSD with TBI | 10 pt VAS-pain intensity, location, frequency | 6 months | Yes | All polytrauma patients | partial correlation coefficients and chi square | PSTD | More patients who reported chronic pain (37%) met criteria for PTSD than did those without pain (15%), chi-squre=5.70, p<.05. Frequency but not severity of chronic pain was associated with PTSD (p<.05) | Fair
Bushnik, 2008(5) | The Experience of Fatigue in the First 2 years After Moderate-to-Severe traumatic Brain Injury: A Preliminary Report | TBI, fatigue/insomnia | Cohort--prospective | All | This study examined the rate and tyes of fatigue that are experienced by a cohort of individuals w. TBI within the first 2 years using a multidimensional fatigue scale. The impact of factors such as demographics, injury severity indices and concomtant psychosocial variables was also examined. | TBI inpatient rehabilitation service | 74% male, age 34 | Inclusion: TBI, admitted to inpatient rehab., Exclusion: medical disorders associated with fatigue | 38 | n/a | n/a | VAS 10 pt. Scale | 1 & 2 yrs. | No | All polytrauma patients | bivariate | None | There were highly significant correlations between levels of fatigue and pain at one and 2 years post-injury (R=.49 and .62, respectively, p<.01) | Poor
Cantor, 2008(6) | Fatigue After Traumatic Brain Injury and Its Impact on Participation and Quality of Life | TBI, fatigue | Case-control | Included (mild to severe TBI) | To examine the relationships between post-TBI fatigue and comorbid conditions, participation in activities, quality of life, and demographic and injury variables | community sample recruited with flyers and advertisements from brain injury clinic | Cases: 53% male, 41% AA, 40% white, 62% severe TBI, age 47.8 Controls: 70% male, 33% AA, 40% white, age 43.0 | Case: Include--TBI, >= 12 months postinjury Exclude: history of non-traumatic brain injury Controls: no history of brain injury | 223 cases, 85 controls | TBI | no TBI | McGill pain questionaire; SF 36 bodily pain | cross-sectional: average of 15 yrs. after injury | No | No | correlations & multivariate regression | Overlap variables, depression sleep score, McGill pain subscales 5 fatigue items | pain is associated w. TBI TBI v. Controls: adjusted McGill pain index rating 17.23 vs. 10.10 (p=.013) SF-36 health survey, bodily pain: 64.7 v. 83.2 (p<0.001 ) post-TBI fatigue has a significant impact on quality of life and well being that are not accounted for by pain, depression and sleep disturbance alone. | Fair
Cosgrove, 1989(7) | A Prospective study of Peripheral Nerve Lesions occurring in Traumatic Brain- injured Patients | causalgia, complex regional/causalgia/autonom, TBI | Cohort-prospective | All | The purpose of this study was to determine the frequency and severity of peripheral nerve lesions occurring in pateint withtraumatic brain injury. | single site inpatient TBI rehabilitaion center | none reported | consecutive pts. admitted to the center | 132 patients, 13 with peripheral nerve injuries | n/a | none | presence and types of pain | variable | No | No | basic descriptive, no comparisons | None | 1. 13 of 132 pateints found to have peripheral nerve injuries 2. 4 of 13 pateints with peripherla nerve injuries had pain, 2 with causalgia, 2 with coplex regional pain syndrome I | Poor
Dawson, 2007(8) | Return to productivity following traumatic brain injury: Cognitive, psychological, physical spiritual, and environmental correlates | TBI | Cohort-- prospective | Included (about 1/2 with > mild TBI) | The purpose of this study was to investigate the determinants and correlates of return to productivity (RTP) defined here as return to paid employment and/or school four years following traumatic brain injury(TBI) | Large regional trauma center | 52% w. mild TBI (others w. more severe TBI), age 27.6, 54% male | Subjects enrolled consecutively over 15 months. Inclusion: non-penetrating TBI, age 16–65, responsive within 1 month of injury Exclusion: previous neurological disorder drug or alcohol abuse, history of illness | 94 enrolled; (47 participated, 50% flu interviews | n/a | n/a | Westhaven--Yale multidimensional pain inventory | Cross-sectional Ave. 4.3 yrs after injury | No | Yes | multivariate regression | Severity of TBI, time to recovery of free recall, depression, pain, coping, stroop interference time | Spearman’s rank correlation coefficient (r) for association between pain and return to productivity: All TBI: 0.50 (p=0.0004) Mild TBI: 0.45 (p=0.03) Mod/Sev TBI: 0.65 (p=0.001) For every unit increase in the log of pain, the odds of going back to work are reduced by 96%. In post-hoc analyses, pain was highly correlated with depression (r=.081). | Fair
Guttman, 1943(9) | Postconcussional Headache | TBI, headache | Cohort-- retrospective | Included: mild to severe TBI | Describe prevalence of headaches in patient with head injury over time | 1 site-- admitted to accident service of infirmary | MVA in 77% | Inclusion: patients admitted for head injury, nonservice cases | 158 | --- | --- | documentation of headaches | 3 and 6 months after injury | Yes | by Head injury severity | descriptive | None | There was no difference in headache prevalence according to head injury severity at 6 months | Poor
Hillier, 1997(10) | Outcomes 5 years post-traumatic brain injury (with further reference to neurophysical impairment and disabilty) | TBI, headache | Cohort -- retrospective | Included: mild to severe TBI | This study collected data on people who had sustained a TBI 5 yrs. previously. Broad outcomes were investigated as well as the specific nature and prevalence of any residual physical impairment and disability | TBI admissions to teaching hospital | age 28.9, 84% male, 69% injuries related to MVA | inclusion: TBI sustained 5 years previously | 67 | n/a | n/a | self report prevalence of pain/location | 5 years | No | No | descriptive | None | 58% of patients had headaches 5 years after TBI. 5% had decreased movement w. musculoskeletal pain | Poor
Hoffman, 2007(11) | Understanding Pain After Traumatic brain Injury | TBI | Cohort--prospective | Included (moderate to severe TBI) | To determine the prevalence of pain at 1 year after injury using a secondary analysis of a prospectively collected sample and to examine possible factors related to overall pain reports in individuals w. TBI. Possible predictors of pain at 1 year were examined as well as factors associated w. pain at 1 yr.. In addition, the relationship of apin, depression, and community participation was explored | single site, university brain injury program | Mean age 36.1, 76% male, 78% white, mean # of injuries assoc. with TBI=2.0 23 of 202 subjects were lost to follow-up. Those who did not complete the SF-36 were more likely to be nonwhite. | Inclusion: primary diagnosis of TBI, age >16, received acute & inpatient rehab care | 146 subjects | n/a | n/a | 2 item bodily pain of SF36 | 1 year | Yes | yes--number of injuries | multivariate regression | Demographics, # and type of injuries, fuctional status at rehab discharge, baseline depression | At one year, 74% of patients have pain, and 55% have functional interference. Baseline Glasgow Coma Scale score was not associated with pain status one year after injury. Pain one year after injury was significantly associated with being female and non-white. Being non-white and depression remained significantly associated with reports of pain at one year in a multivariate regression model (taking other factors into account). | Good
Lippert-Gruner, 2007(12) | Health-related quality of life during the first year after severe brain trauma with and without polytrauma | TBI | Case control | All | Investigate health related quality of life in TBI pts with and without additional injuries | Not specified | Not specified | Not specified | 49:28 w. severe TBI and 21 with severe TBI and additional injuries | TBI with additional injuries | TBI alone | SF 36--Bodily Pain/function | 6 & 12 months | No | No | descriptive | None | No difference in bodily pain according to whether pt had additional injuries in addition to TBI | Poor
Masson, 1996(13) | Prevalence of impairments 5 years after a head injury, and their relationship with disabilities and outcome | TBI | Cohort--prospective | All | To determine what consequences cognitive behavioral or somatic complaints had on disabilities and recovery after head injury | admission to 1 of 3 trauma centers in France | 51% age 15–29, 29% 30–44,19% 45–59, 75% male, 72% injured in MVA | Inclusion: patients admitted to trauma center with multiple injuries including head injury, age >15and <60 | Cases: 231 pts. W. TBI ; 80 lower limb injury pt. Controls | n/a | n/a | self report of headache and other pain | 5 yrs after injury | No | Yes | bivariate comparisons | Stratified by head injury severity | The prevalence of headache was 44–54%, significantly greater than 16% in a comparison group with lower limb injury but no TBI. Headache and other pain prevalence is not significantly associated with head injury severity | Fair
Olver, 1996(14) | Outcome following traumatic brain injury: a comparison between 2 and 5 years after injury | TBI, headache | Cohort--retrospective | Included | This study examined longterm outcomes in traumatically brain-injured individuals following discharge from a comprehensive rehabilitation programme. | Comprehensive rehabilitation programme | 65% male, meane agewith GCS <=12, 89% with PTA> 7 days | Consecutive admissions to inpateint rehab unit between 3/85 and 1/89 who completed 2 year with 5 year interviews | 103 | --- | --- | headaches | 5 yrs after injury | No | No | bivariate comparisons | None | Headache prevalence increased from 31% at 2 yrs to 42% at 5 yrs | Poor
Walker, 2005(15) | Headache After Moderate and Severe Traumatic Brain Injury: A Longitudinal Analysis | TBI, headache | Cohort--prospective | All | Main objectives were to describe posttraumatic headache in acute rehabilitation patients with moderate and severe TBI and assess the course of post-traumatic headache over time. | (4) VA Polytrauma Network site Brain injury (rehab units) | Veterans-- Age 28.4, 91% male, 67% white, 73% injured in MVA, 6% penetrating injuries | Inclusion: consecutively admitted patients with moderate to severe TBI, veteran, cognitve function core greater than/equal to 5 (Rancho Los Amigos Scale | 109 | n/a | n/a | headache frequency, location, type, degree of incapacitation, headache density | 6 & 12 months | Yes | All polytrauma patients | primarily bivariate, between group comparisons | --- | Nearly 38% (41/109) of patients had acute headache symptoms; most often in a frontal location (20/41), most often of daily frequency (31/41) and showing no relation to injury severity, emotional, or demographic variable. Among patients with headaches at admission, 54% reported persistent headache symptoms at six months, and of this group, 96% still had headaches at 12 months. Headache improvement was associated with less anxiety and depression at 6 month followup. | Fair
OTHER INJURIES
Brenneman, 1997(16) | Long-term outcomes in open pelvic fractures | Orthopedic injuries | Cohort-retrospective | | To document the injury characteristics, complications, and outcomes of trauma victims with an open pelvic fracture. We directed particular attention to two interventions under the control of trauma surgeons: blood transfusion and the use of a diverting colostomy. We also focused on 3 outcomes that occur only after the patient has left the trauma center: functional status, overall health perception, and return to work. | Sunnybrook Health Science Centre (SHC) is an adult regional trauma unit that treats mostly patients with blunt trauma (90%); 1987–1995 | Patients with open fractures, n=44 Mean age 30, range 15–46 75% male Mechanism of injury: 27% motorcycle crash, 25% pedestrian, 21% motor vehicle crash Mean ISS 31, range 10–75 Patients with closed fractures - n=1,135 Mean age 39, range 12–93 57% male Mechanism of injury: 57% motor vehicle crash, 19% pedestrian Mean ISS 30, range 5–75 Major risk factors for open pelvic fracture: typical patient was a young male, frequently involved in a motorcycle crash, and more likely to have a severe unstable pelvic ring fracture. | All multiple system blunt trauma victims with a pelvic fracture admitted between Jan 1987 – July 1995 classifed as having either open or closed fractures. | 27 of 33 long-term survivors were available for followup | Open pelvic fractures | Closed pelvic fractures | Long-term survivors of an open pelvic fracture were assessed by phone interview using SF-36 and FIM. Additional Qs were on patient’s employment, sexual functioning, and bowel and bladder function. Global health assessment, scale 0–100. | Mean followup 4 years after injury | Yes | All polytrauma | Comparison of means | None | SF-36 subscale mean score, open fractures (n=27) v. closed fractures (n=84) Bodily pain: 55.6 v. 66.1, p =ns Concludes: Patients with open pelvic fractures need to be treated with massive blood transfusions and often require a colostomy. They are frequently left with chronic pain and residual disabilities in physical functioning and physical roles, and many remain unemployed years after injury. | Fair
Hebert, 2000(17) | The effect of polytrauma in persons with traumatic spine injury. A prospective database of spine fractures | Orthopedic injuries: spine injury | Cohort-prospective | Majority. | 1) to attempt to define predictors of injury severity in patients who sustain traumatic spinal injury; 2) to identify immediate, early, and late outcomes that are associated with severe or multiple injuries in this population. A 2nd objective was to determine whether one particular type of associate injury or region of injury is most predictive of outcome in these patients. Hypothesis: a higher severity of associated injuries adversely affects outcome in patients with traumatic spine injuries. | Single hospital, all consecutive patients with traumatic spine injury; 1983–1992 | patients with traumatic spine injury Mean age 32 71.7% male Mean ISS score 17.3 (range 4–75) Most common causes of injury: 58.9% MVA 17.6% sport or recreational injury 35.3% of patients had neurologic impairment. 71.7% of patients had polytrauma | Database of 830 spine trauma patients admitted consecutively to Univ of Alberta Hospital btw 1983–1992. Traumatic spine injury: spine fracture, dislocation, or subluxation, with or without neural injury. Excludes pathologic fracture without trauma, soft tissue or ligamentous injury without radiographically identified spine abnormality, and atraumatic injury. Excluded patients with only a minor transverse or spinous process fracture. | 830 | Severity of injury, quanitified by using AIS and ISS | --- | Immediate outcomes: Neurologic impairment Loss of consciousness, low cervical injury, thoracic injury, multiple noncontinguous fracture, mixed fracture Early outcomes: early complications, complications requiring surgery, surgical treatment, death in hospital Late outcomes: no return to work at year 2, incapacitating pain year 1 incapacitating pain year 2. Only the late outcomes are abstracted here. | Immediate, early, up to 1 or 2 years | Yes | No | Pearson's correlation coefficient. General factorial analysis of variance of nominal data with ISS as the dependent variable. Multiple linear regression for the association of each AIS region to FIM scores at discharge, 1 year, and 2 yrs after injury | Not reported | Late outcomes: ISS had a significant negative correlation with FIM score at discharge, 1 year, and 2 years after injury. With stepwise linear regression, the AIS region accounting for most of the variance in FIM score was the spine (R2 0.383 at discharge, 0.429 at 1 year, 0.338 at 2 years) followed by the thorax at 1 year (R2 change, 0.005). 66% of patients returned to work by 2 years after injury. Those who did not return to work had significantly higher ISSs than those who returned to work: Mean ISS 22.65 v. 16.95, p<0.0001. Pts with higher ISS were more likely to have incapacitating pain v. occasional pain at 1 year (mean ISS 22.42 v. 14.99, p=0.001) and were more likely to have incapacitating pain (mean ISS 23.37) v. no pain (ISS 16.49) or occasional pain at 2 years (ISS 16.14), p=0.003. A letter by P.Anderson pointed out that defining polytrauma as an ISS of >9 is a much lower cutoff than that used in previous studies, and can reflect only moderate trauma to the spine, i.e., a spinal injury with a neurologic deficit and not truly multisystem trauma. A more commonly used value for the ISS is 18. Anderson also points out that the 39% lost to followup at 2 years may likely have better outcomes than those with permanent injuries who would continue with ongoing medical care or vocational rehabilitation. The FIM was designed to evaluate the neurologically impaired, especially quadriplegic patients, and might not have been useful in determining outcomes of extremity, chest, or abdominal trauma. Thus the results could have been biased to show that neurologic injury (i.e. severe spinal trauma) was the greatest predictor of outcome | Fair
Tran, 2002(18) | Functional outcome of multiply injured patients with associated foot injury | Orthopedic injuries: foot injuries | Case control | All | To evaluate the ability of the AAOS lower extremity and foot and ankle questionnaire to discern a difference in outcome of polytrauma patients with and without foot injuries. | single institution trauma registry | Pts with v. without foot injuries: 85.7% v. 78.6% male Mean age = 29 v. 32 Mean ISS = 15 v. 17 Foot injuries included calcaneal fractures, Lisfranc fractures, talar fractures, midfoot fractures, and metatarsal fractures, with 2 pts suffering open injuries. Defined polytrauma as having an ISS >9. ISS scores >9 are associated with neurologic impairment or additional regions of injury. 71.7% of patients by this definition sustained polytrauma, with a mean ISS score of 20.56 +−10.83. 28.3% had only spine fracture with no associated injury, with a mean ISS score of 8.95 +−1.90. | Included 14 polytrauma patients with a foot injury, and 14 polytrauma patients without a foot injury. Each of these groups of patients were randomly selected from the institution's trauma registry. Inclusion criteria were: a minimal ISS of 12; survival of inintial injury with a minimum of 12 months of follow-up, and willingness to participate in a telephone survey. | 14 pts with foot injuries; 14 pts without foot injuries. | An AAOS lower extremity core questionnaire and foot and ankle; data gathered by chart review and telephone survey | Polytrauma without foot injuries | Chart review gathered data on age, sex, type of foot injury, and ISS. The questionnaire includced the SF-36, and 3 lower extremity scores (physical health and pain, treatment expectations, and satisfaction with symptoms), and 2 foot and ankle scores (global foot and ankle scale and shoe comfort). | Not specified. Inclusion criteria required that patients have survived at least 12 months after injury. | Yes | No: all subjects PT | The results between the 2 groups were compared using a 2-tailed unpaired T-test with a p < 0.05 considered significant. | None | Patients with foot injuries had a dramatically lower physical function, role physical ( a perception of their physical functioning), bodily pain, and social function scores compared to the control group. All 5 of the scales specific to lower extremity and foot and ankle questions were significantlly different, with lower physical health and pain scores, treatment expectation scores, and satisfaction with symptom scores, global foot and ankle scale scores, and shoe comfort scores, among patients with foot injuries. In 5 of the 10 SF-36 scores, patients in the foot injury group had significantly lower scores. With v. without foot injuries: Mean SF-36 score: Physical function 80.7 v. 38.9, p<0.05 Role-physical 87.5 v. 41.1, p<0.05 Bodily pain 81.9 v. 50.6, p<0.05 Social function 96.6 v. 67.9, p<0.05 Physical composite score 47.8 v. 30.8, p<0.05 In all 5 off the lower-extremity scores, the foot-injured group had lower scores than the control group: Physical health and pain: 83.3 v. 43.5, p<0.05 Treatment expectations: 83.8 v. 55.7, p<0.05 Satisfaction with symptoms: 4 v. 1.5, p<0.05 Global foot and ankle scale: 100 v. 57.6, p<0.05 Shoe comfort: 100 v. 18.9, p<0.05 | Fair
Turchin, 1999(19) | Do foot injuries significantly affect the functional outcome of multiply injured patients? | Orthopedic injuries: foot injuries | Cohort study- Prospective, matched pair | All | 1) To assess the functional outcome of a specific subgroup of trauma patients, that is, multiply injured patients with foot injuries. 2) To determine which measures are most appropriate for assessing the functional outcome of these patients. | University-affiliated Level 1 trauma center with a prospectively entered trauma database. | In 28 pts with foot injuries: 60.7% male (n=17 males; 11 females) Mean age 34 years (range 18–63); Mean ISS 25 (range 13–41); Mean hospital stay = 24 days; Mean ICU stay = 5 days; Mean duration of followup = 62 months Foot injuries were calcaneal fractures (n=13), talar fractures (n=6), Lisfranc fracture dislocations (n=4), other midfoot fractures (n=4), metatarsal fractures (n=8), and phalangeal fractures (n=2) In 28 pts without foot injuries: Mean age was 36 (range 16–70); Mean ISS 25 (range 13–41) Mean hospital stay = 25 days; Mean ICU stay = 7 days; Mean duration of followup = 69 months No significant btw-group differences in demographics. | 28 multiply injured patients with foot injuries were identified in a prospectively entered trauma database. These patients could then be matched in a blinded fashion to multiply injured patients who did not have foot injuries but were of the same sex, and within 10 years of age, within 5 points of the ISS, and within 1 year of follow-up. | 28 with foot injuries; 28 without foot injuries | Polytrauma plus foot injuries; data gathered by telephone survey | Polytrauma wihout foot injuries Prospective matched pair analysis. Does not describe the other non-foot trauma injuries that the patients sustained, in order to qualify as "multiply injured". | Outcomes were determined by telephone survey. SF-36, a global health measure with 8 components: physical functioning, role physical, bodily pain, general health, vitality, social functioning, role emotional, and mental health. WOMAC, a disease-specific scale designed to measure status of patients with osteoarthritis of the lower extremity. 3 components: physical function, pain, and stiffness. Modified Boston Children's Hospital Grading System, a foot-and-ankle score for assessing patients with ankle arthrodeses. 2 components: pain, physical function (a 3rd, range of motion, could not be assessed by telephone, and was omitted). | 2 years minimum. Mean followup 62 months. Cases and controls were matched on timing of followup (within 1 year of each other) | Yes | No: all subjects PT | 2-tailed unpaired t tests to assess whether foot injureis affect the outcome of multiply injured patients. The correlation of the 3 outcome measures was assessed for both groups of patients to determine the relative usefulness of the scales. | None | Response rate to telephone survey not reported. The outcome of multiply injured patients with foot injuries was significantly worse than that of patients without foot injuries when using any of the 3 outcome measures. Patients with v. without foot injuries: Mean SF-36 score: 49 v. 66 (p=0.008) Mean total WOMAC score: 34 v. 13 (p=0.00007) Mean modified Boston Children's score: 634 v. 78 (p=0.001) | Fair
Urquhart, 2006(20) | Outcomes of patients with orthopaedic trauma admitted to level 1 trauma centres | Orthopedic injuries | Cohort-prospective | Included: 2 of 3 subgroups have multiple injuries | To investigate the outcomes of patients admitted with a variety of orthopedic injuries to 2 adult Level 1 trauma centers in Victoria, Australia. | Victorian Orthopedic Trauma Outcomes Registry - all pts with trauma admitted to the 2 adult Level 1 trauma centers in Victoria, Australia; August 2003–2004 | 893 completed the 6-month follow-up, out of 1181 eligible. | VOTOR trauma registry includes all pts with an orthopedic injury admitted over a 12 month period (Auguest 2003–2004) to the 2 adult Level 1 trauma centers in Victoria, Australia. Excludes patients that had a pathological fracture related to metastatic disease and/or an isolated orthopedic injury managed by another unit. Also excluded pts with a diagnosis of dementia or mental illness, or were less than 6 months post- injury. | 659 pts with multiple orthopedic injuries (with no other injuries) 165 patients with single/multiple ortho injuries plus other injuries | 1) Patients with multiple orthopedic injuries (with no other injuries 2) Patients with single/multiple orthopedic injuries and other injuries. | Patients with an isolated orthopedic injury, with no other injury | Pain, disability, SF12 assessed at 6 months post-injury by questionnaire. All patients were initially contacted by phone to complete the questoinnaires. Questoinnaires were mailed to patients who could not complete it at the time of the call. | 6 months post- injury | Yes | Yes | Mann-Whitny U-test to compare continuous variables, such as age, pain at 6 months and SF12 physical and mental scores. Chi2 tests for associations between injury groups and categorical variables. | None | Moderate/severe pain at 6 months was most frequent among pts with single/multiple ortho injuries plus other injuries (46.7%), compared with 36.9% of patients with multiple ortho (without other) injuries, and 32.5% of patietns with an isolated ortho injury. P<0.05 for differences between groups. MOderate/severe disability was more frequent among these groups in a similar pattern (52.7% v. 50.3% v. 44.1%, p<0.05 groups 2 and 3 v. 1), although the 2 groups with multiple injuries did not differ from each other. % not working at all post-injury was highest in the group with single/multiple ortho plus other injuries (42.5%), compared with multiple ortho injuries only (38.2%) and isolated injuries (18.8%). (p<0.05 group 1 differs from 2 and 3) | Fair
Zelle, 2005(21) | The impact of injuries below the knee joint on the long- term functional outcome following polytrauma | Orthopedic injuries: below- knee injuries | Cohort study | All | The purpose of the Hannover Rehab Study was to identify specific variables that are predictive of the long- term outcome following polytrauma. To evaluate the impact of injuries below the knee joint on the long- term functional outcome following polytrauma. | Hannover Rehab Study: cohort study, Germany; 1973–1990 | 389 patients: 287 (74%) male Mean follow-up 17.3 +− 4.8 years Mean age 25.4 Mean ISS 20.2 Mean PTS 29.5 | 637 polytrauma patients who were treated at the study site between 1973–1990 were re-evaluated by a doctor on an outpatient basis. Patients were enrolled in the study by these criteria: -Polytrauma between 1973–1990 associated with one or more lower-extremity fractures. -Treatment at our level one trauma centre -Aged 3–60 at the time of injury -Minimum follow-up of at least 10 yrs 389 were eligble for the study - report suggests that all eligible were followed up. | 389 | Injuries below the knee joint | Injuries above the knee joint | patients treated at trauma center betw 1973–1990 were re-evaluated by a doctor on an outpatient basis, usgin a standardized self-admiinistered patient questionniare and a standardised physical exam of the injured body regions, including the modified Karlstrom-Olerud score, Lysholm score, range of motion of hip, knee, and ankle joint, weight bearing status of the injured lower-extremity, persistent pain of the injured lower-extremity, and gait. General outcomes measured include the Hannover score for polytrauma outcome (HASPOC), 12-item short-form health survey (SF-12), Tegner activity score, and the inability to work. Ability to work at followup was only assessed among subjects under age 63 | 10+ years post injury | No, but part as functional status scale | All polytrauma patients | 3 groups were compared, based on pattern of injury: 1) injured lower extremities with fractures above knee joint; 2) fractures below the knee joint but without associated unilateral fractures above knee joint; 3) combined fractures above and below the knee joint. General outcomes compared 2 groups: 1) fractures below the knee joint on at least one side (including combined injuries); 2) patients with lower-extremity fractures solely above the knee joint. Logistic regression for each outcome measurement for below-knee group, with above knee group as reference | Logistic regression adjusted for age, gender, and ISS - these variables were significantly different between patients with injuries above and below knee. | Below knee (n=156) v. combined injuries (n=170): Persistent pain: 45.5% v. 58.8%, p=0.016 Above knee (n=183) v. below knee (n=156): Persistent pain 39.3% v. 45.5%, p=0.252 Above knee (n=183) v. combined injuries (n=170): Persistent pain 39.3% v. 38.8%, p<0.0005 Inability to work: Fractures below the knee joint v. above knee joint: OR 2.21 (1.10–4.43) concludes: Fractures below the knee joint have a significant impact on the functional recovery following polytrauma. | Good
Anke, 1997(22) | Long-term prevalence of impairments and disabilities after multiple trauma. | long-term followup | Cohort- retrospective | All | To analyze the prevalence of impairments and disabilities after sever multiple trauma. Specifically, to address the following questions: To what extent is the injury-type and severity predictive of late impairment and disabilities? To what extent does the trauma cause changes in the quantity and quality of social networks? To what extent do demographic variables and impairments influence the ability to manage personal activities of daily living, nonwork activities, and work? | Ulleval Hospital in Oslo, Norway | 70% male. Mean age at time of injury 33 +/−16 years. 71% had higher education. Among the subjects regularly working or studying at the time of injury, 14 blue-collar, 44 white collar (including 15 students). Mean ISS=25 (range 17–50). | Inclusion : All patients with severe multiple trauma; Age >=12 yrs; Admitted within 24 hours of injury to the department of surgery at the Ulleval Hospital in Oslo during 1990; ISS>16. Exclusion: <12 yrs (n=3); Dead (n=5); Living abroad (n=9); Unknown address (n=5); Subsequent serious injury (n=1). | N enrolled=69 | Abbreviated Injury Scale; Demographic variables; Social network questionnaire; Occurrence of impairments and disabilities | [compared to general population] | Social network; Impairments; Disabilities | 35 +/−4 months post injury | Yes | no, all patients included are polytrauma patients | Ror comparisons of groups of data simple cross tabulations were performed Chi-Squared test or Fischer's exact test. Correlations were analyzed with Spearman's P. The Mann-Whitney nonparametric two- sample test was used to analyze differences in medians. The sign test was used to analyze the changes in activity preferences. Values of p of <= 0.05 were considered statistically significant. | None | Associations between all Leisure Disability (LD) (n=51) & Vocational Disability (VD) (n=11) and other factors: Age LD=ns; VD=p<0.01; Blue/white-collar work LD=ns; VD=p<0.05. Decrease of social network quantity LD=ns; VD=p<0.05; Decrease in social network quality LD=ns; VD=p<0.01; Injury severity score LD=ns; VD=p<0.05. Cognitive impairment LD=ns; VD=p<0.05; Physical impairment LD=p<0.01; VD=ns; Pain LD=p<0.05; VD=ns. Numbers of lost leisure activities LD=N/A; VD=p<0.05. | Fair
Brenneman, 1997(23) | Long-term outcomes in blunt trauma: who goes back to work? | long-term followup | Cohort-prospective | Not specified, mean ISS=25 | To compare the characteristics of patients who do and do not return to work after blunt trauma. | Sunnybrook Health Science Center (a regional trauma unit that admits the majority of adult multiple system trauma patients in Toronto and surrounding areas in the province of Ontario Canada). | 65% male. Mean age=37. Mean ISS=25. | Inclusion: Discharged from the hospital between July 1994 and June of 1995. Exclusion: ISS<=10; Patients who left with incapacitating head injuries. | N enrolled = 195 | Questionnaire at time of discharge and phone interview 1 yr post injury. | general population | Return to work (RTW) | 1 yr post injury | No | All polytrauma patients | Two regression models | None | Factors associated with RTW: younger age (p<0.0001); professional employment (p<0.0001); lower ISS (p<0.001). | Fair
Dimopoulou, 2004(24) | Health-related quality of life and disability in survivors of multiple trauma one year after intensive care unit discharge. | long-term followup | Cohort-prospective | All | To evaluate health-related quality of life and disability in multiple-trauma patients requiring intensive care unit management. | A tertiary teaching hospital in Athens, Greece. | 74% male. Mean age=31. Mean 1SS=22 (11–41) | Inclusion: all consecutive multiple-trauma patients admitted in the ICU during the period of 1999–2000. Exclusion: not described | N eligible patients=117. N enrolled= 87 | Questionnaires at 1 yr post injury | general population | Nottingham Health Profile, Glasgow Outcome Scale and Rosser Disability Scale | 1 yr post injury | No | All polytrauma patients | Normality of the distributions of variables was examined using the Komogorov-Smirnov test. Relationships between variables were analyzed by Spearman’s correlation coefficient. To identify factors predicting HRqoL and disability, logistic regression analysis was performed. | None | Factors associated with lower score on Nottingham Health Profile: higher ISS (p=0.008) & head injury (p=0.038). Factors associated with disability (Rosser Disability Scale): higher ISS (p=0.004) & head injury (0.004) | Fair
Fitzharris, 2007(25) | General Health Status and Function al Disability Following Injury in Traffic Crashes | long-term followup, car accidents | Cohort-prospective | Included | To examine general health status and functional disability at 2 months and 6–8 months post-crash | A major trauma center and 2 metropolitan teaching hospitals in Victoria, Australia | 35 males, 27 females Mean age 35.3 (males), 38.7 (females) % employed; 100% males, 96.3% females Mean ISS: 9.5 males, 11.1 females; 10.2 total % with major trauma, i.e. ISS >15: 14.3% males, 18.5 females; 16.1% total 48% had fracture of lower extremity, and 61.3% had fracture of upper extremity. More males than females had fractures of lower leg (37.1% v. 14.8%, p<0.05). | Healthy adults aged 18–59 admitted to hospitals following involvement in a road traffic crash. Excluded those with moderate-severe head injury and spinal cord injury. Unclear whether analysis included all eligible patients, or a sample (those with data from all 3 timepoints). | 62 adults completed interviews prior to discharge and at 2 and 8 months post-discharge | traffic accident | differences over time; differences by gender | Self-reported pain, using 100-pt VAS, assessed by interviews on 3 occasions: discharge, 2-months and 8 months post-discharge. | 2 months and 8 months post-discharge | Yes | No | Comparisons between males and females were made using chi-square tests, and 2way repeated measures ANOVA using a mixed design 3(time) x2 (gender) with planned comparisons between timepoint scores. | Gender, and time | There were no significant differences by gender in self-reported pain (100-pt VAS scale) at 8 months post-discharge. At 2 months post-discharge, the % reporting Zero pain was 11.4% of males, and 3.7% of females. At 8 months: 20% of males, 22% of females. | Fair
Holtslag, 2007(26) | Determinants of long-term functional consequences after major trauma. | long-term followup | Cohort-prospective | Majority | To quantify the prevalence and determinants of the functional outcome of severely injured patients, studying the influence of sociodemographic, injury-related factors, and of physical factors. | University Medical Center Utrecht, 1 of the 10 Level I trauma hospitals in the Netherlands, serving a catchment area with population if 1.1 million. Utrecht is an urbanized area in the center of the Netherlands with a population density of 813 inhabitants per square kilometer. | 74% male (Mean age= 36.6) 36% female (Mean age=41.0 years) | Inclusion: Severely injured patients referred from emergency care during 1999 and 2000; ISS>16. Exclusions: Age<16 | N eligible patients=359; N enrolled=311 | self-administered questionnaires | general Dutch population | Health status as measured by EQ-5D; Disability as measured by Glasgow Outcome Scale; Head injury symptom checklist (HISC); Comorbidity using health and labor questionnaire from which depression was excluded. | randomized range of 12 to 28 months after trauma | only as part of EQ-5D | comorbidity is analyzed as a predictor of outcomes | The outcomes of the five individual EZ dimensions were dichotomized as no problems vs. some or severe problems. Also dichotomized, symptoms of cognitive yes/no as well as functional limitations yes/no. Other determinants divided into two groups were gender, age, injury severity, localization of injury, education, bmi, sports activities before injury, depression and comorbidity. dichotomized determinants and dichotomous outcomes were tested with Pearson Chi-Squared test; between dichotomized determinants and linear outcomes Mann-Whitney U test. the adjusted impact of the potential determinants on all dichotomized outcome variables was determined by mans of multivariate logistic regression analyses. | no | Factors associated with poor Glasgow Outcome Scale (general disability) as significant according to Chi-Squared test: aged 55 or older; Brain injury; Spinal cord injury; Low educational level; Comorbidity. Factors associates with lower EQ (quality of life) scores: Education (p<0.05); Comorbidity (p<0.05); Education (p<0.05); Brain Injury (p<0.05); Spinal cor injury and lower extremity injury (p<0.001). | Fair
MacKenzie, 1998(27) | Return to work following injury: the role of economic, social and job-related factors. | long-term followup | Cohort-prospective | Included | To examine factors influencing return to work for severe fracture to the lower extremities. | Patients recruited from three level-1 trauma centers: Harborview medical Center (Seattle, WA), the R Adams Cowley Shock Trauma Center (Baltimore, MD) and Vanderbilt University Medical Center (Nashville, TN) | Aged 18 to 64, worked full time before the injury | Inclusion: P atients admitted for treatment of blunt, unilateral lower extremity fracture distal or including the acetabulum. Exclusions: patellar fractures and minor foot fractures; Patients who recieved definitive care outside the trauma center; Had a major neurologic injury, an unstable spinal cord injury, or an upper extremity injury that precluded the use of crutches or walker; Had a psychiatric illness; Had lower extremity fracture secondary illness; No English spoken; Did not live in the trauma center’s catchments area; On active military duty | N elegible=341; N enrolled=312. | patient interview and evaluation by physical therapist | general population | Time in days from injury to first time the study participant returned to work | 1 yr post injury | No | No | Log-rank test used to test the association between the cumulative probability of RTW and each risk factor considered one at a time. A cox proportional hazards regression model was used to estimate the combined effect of multiple risk factors while accounting for the effect of pain and impairments. | Effect of impairment; Pain | Factors associated with higher rates of RTW (P<0.05): Higher levels of education, Family incomes above 125% of the federal poverty level, High levels of social support (particularly in terms of available practical assistance), Absence of alcoholism, Job stability, Job flexibility, White-collar employment, Employment in jobs with low physical demands. Both the receipt of workers’ compensation and involvement with the legal system were associated with lower rates of RTW. Pain was highly correlated with impairment. | Good
Meerding, 2004(28) | Distribution and determinants of health and work status in a comprehensive population of injury patients. | long-term followup | Cohort-prospective | Included | To answer the following questions: How are the levels of functioning and work status distributed across patient groups in the first year after injury? How does the health status of injury patients compare with the general population? What personal, injury and health care factors are predictive for levels of functioning and work status? | Hospital emergency departments of the Dutch Injury Surveillance System. 17 hospitals in the Netherlands (approx. 15% coverage) These hospitals are geographically spread across the country; include both academic and nonacademic hospitals, trauma centers, and nontrauma centers; and cover representative amounts to urban and rural populations. | 54% Male. 72.6% <65yrs. | Inclusion: Visited one of the hospital emergency department in the system with an injury. Exclusion: Age<15; Victims of self- inflicted injury; Institutionalized persons. | N eligible=4639. N enrolled=1806. | questionnaire (postal) EuroQuol (EQ-5D) and EQ-5D+ (for cognitive function) as well as return to work status | EuroQol data from the Swedish general population | responses to EQ5+ as well as return to work status | 2 mo, 5 mo and 9 mo after injury | pain as part of functioning and health measured by EQ5+ as well as return to work status | Yes | A nonresponce analysis was performed by forward stepwise multivariate logistic regression separate for the 2, 5 and nine month measurements. Regression analyses on the weighted data of each follow-up measurements. The sociodemographic and injury-related characteristics were tested as significant predictors of functional outcome and wok status in forward- step multivariate regression analyses. they were all entered as categorical variables. | Age, Sex, Education level, | Number of injuries is a determinant of health and work status. Factors associated with poor QoL (EQ-5D): Age (P<0.0001); Sex (P<0.001); LOS times type of injury (p<0.05); Education(P<0.01). Factors Associated with RTW: Hospital LOS (p<0.0001); Admittance to ICU (p<0.05); Education (P<0.01). | Good
Mkandawire, 2002(29) | Musculoskeletal recovery 5 years after severe injury: long term problems are common. | long-term followup | Cohort-prospective | Majority | To report the incidence of functional problems and pain for different types of injuries: shoulder girdle, upper limb, lower limb and pelvic injuries. | Sixteen hospitals in a large geographical area, Mersey Region and North Wales. | Mean age=36.5. All were severely injured “usually involving several body regions” | Inclusion: In a 12 month period in 1989–1990 patients discharged alive from a hospital having sustained severe injuries. Exclusions: Reside outside an area around the research centre, where follow-up appointments at hospital or home visits could feasibly be arranged. | N enrolled =158 | disability was assessed and graded by an assessor after an interview and detailed physical examination using the Bull Disability Scale. Pain was graded by the patient according to undefined categories, none, mild, moderate or severe | none; compared to patients from EPITOME study not studied in this study | Single assessment of functional disability and pain | 5 years post injury | Yes | Yes; single fractures compared to multiple fractures | descriptive statistics | None | 44% of patients with single fractures had residual disability. 90% of patients with multiple fractures had residual disability. | Fair
Soberg, 2007(30) | Long-term multidimensional runctional consequences of severe multiple injuries two years after trauma: a prospective longitudinal cohort study | long-term followup | Cohort study- Prospective | All | To explore the functional health status and disease burden of patients with severe multiple injuries from after the return home until 2 years after injury. | Ulleval University Hospital in Oslo, Norway, a trauma referral center with a population base of nearly 2.5 million people and approximately 900 trauma team activations each year. | 83% male. Mean age=35.3; 72% high school or higher; 55% married or living with partner; 63% blue collar workers | Inclusion: Aged 18–67; New Injury Severity Score (NISS)>=16; At least two injuries classified in the abbreviated Injury Severity Scale (AIS) injury scoring system. Exclusion: Former multiple injuries; Burn injuries only; Substance addiction; Severe psychological disease registered in medical record; Aphasia; Insufficient command of the Norwegian language. | N elegible=169. N enrolled=101. | Questionnaires including the following instruments: SF–36; WHODAS II; COG scale (plus demographic data) | none; compared to general population scores or patients from MacKenzie study | SF-36: Physical functioning; Role physical; Bodily pain; General health; Vitality; Social functioning; Role emotional; Mental health, COG, WHODAS II also injuries were rated by approved trauma registrar for severity (1–6) and location (head/neck; face; chest; abdomen/pelvic content; extremities; external) | at time of injury upon discharge from hospital, 1yr post injury & 2yr post injury | Yes | All polytrauma patients, compared against general population | Descriptive statistics; for non- parametric data: chi-squared tests, spearman’s p or Pearson’s r. for parametric data t tests and ANOVA. For multiple comparisons, Bonferroini correction | Yes | Head injury patients scored an average of 13.7 points worse on COG scale at 2 yr post injury (p=0.002). 2 years post injury the most important predictor variable for role physical were physical functioning both shortly after return home and 1 yr after injury (p<0.00001). Variables at 1 year after injury that predict role physical at 2 years were profession (p=0.019), social functioning (p=0.047) and physical functioning (p<0.001). For WHODAS II (disability rating) predictors for a low disability rating at year 2 were: time from injury to return home (p=0.001), social functioning (p<0.001) and physical functioning(p=0.003); Predictors at year 1 were: profession(p=0.017), injury severity (p=0.0001), bodily pain (p=0.042), social functioning (p=0.030), physical functioning (p<0.001) and cognitive function scores (p=0 002) | Good
Vles, 2005(31) | Prevalence and determinants of disabilities and return to work after major trauma. | long-term followup | Cohort-prospective | Included | to assess the prevalence and determinants of disabilities and return to work after severe injury | St. Elisabeth Hospital in Tilburg, the Netherlands, one of the 10 regional Level I trauma centers in the Netherlands. | 81% male; mean age=33; Mean ISS=23. 19% female; Mean age=37; Mean ISS of 23. | Inclusion: Trauma patient admitted to St. Elisabeth Hospital between Jan 1996 and Jan 1999 with an ISS >=16 Exclusion: not reported | N elegible =295; N enrolled=166 | written questionnaire or a telephone interview | general population | EQ-5D-pain and discomfort scale Glasgow Outcome Scale and return to work status | 1 yr post injury | No | not stratified but one of the determinants is number of inured body parts (one, two, two or more) | outcomes of eq-5d dichotomized to no problems/problems and tested by pearson chi-squared test. Index scores were compared using the Mann Whitness test for comparing two groups and Kruskal_Wallis test for ordered groups. Multivariable analyses were performed to evaluate joint effects on outcomes. | None | Factors associated the pain or discomfort dimension of the 5Q-5D are: ISS>=25 (p=<0.05); gender=female (p=<0.05); Injury to the chest or thoracic contents (p=<0.01); Injury to remaining body areas (not head, abdomen, chest, spine or extremity) (p=<0.01). | Fair
Dougherty, 1999(32) | Long-term Follow-up Study of Bilateral Above the Knee Amputees from the vietnam War | Amputation, quality of life | Cohort study--retrospective | All | To document long-term outcomes for pts. Who had a bilateral above the knee amputatoin during the vietnam war | pts. Seen in a single hospital during vietnam war. Pts. Were contacted years later and asked to complete this study. | Veterans mean=47.8 a time of survey(27.5 yrs after injury)91% married | only inclusion is having a apecific type of surgery at a certain hospital during the vietnam war | 23 cases and 145 age and gender-matched controls from a national registry | none | none | SF=36 scores (including bodily pain) | given questionaire 27.5 years ( on avg.) after surgery | Yes | No | bivariate comparisons | None | Amputation smple scored lower on the physical functioning scale of the SF-36. Comparisons on the other 7 subscales revealed no significent differences. A third of sample continued to use prosthetics(25 + yrs. Post-injury) | Poor
Dougherty, 2001(33) | Transtibial amputees from the Vietnam War. Twenty-eight-year follow-up | Amputation, transtibial headache veteran | Cohort--retrospective | Majority | To compare long-term functional outcome btw 2 groups: 1) An isolated amputation 2) Amputation and at least 1 other major injury All had transtibial amputation. | Retrospective chart review of pts seen for transtibial amputation during the Vietnam War. These pts were then recontacted an avg of 28 years later, and asked to complete questionnaires | Veterans, race not specified Group 1 v. Group 2: Mean age 48.9 v. 48.1 Employed 100% v. 98% Married 93% v. 98% Kids 82% v. 84% History psych Tx = 21% v. 50% | Underwent transtibial amputation at a specific hospital during Vietnam war. only subset used to match the control group, based on age | N = 72 total Group 1, n=28 Group 2, n=44 | n/a | none | SF-36 scores (including bodily pain) | 27.5 years ( on avg.) after surgery | Yes, is one of several QOL indicators examined | Yes | bivariate comparisons | None | Polytrauma group scored significently lower on a measure of QOL compared w. a control group. polytrauma was not directly compared to single trauma | Fair to poor
Frink, 2007(34) | Long term results of compartment syndrome of the lower limb in polytraumatized patients | KQ2,4: compartment syndrome, non-veteran | Cohort study--retrospective | Majority | Examine outcome of cmpartment syndrome of lower limb in patients with multiple injuries versus patients with single injury p. 608 | a single hospital | 65 % male, 38.0 +/− 4.4 at time of injury, race not specified | I: <80 yrs old treated for compartment sydrome betwee '99-'04 E: other injuries that could cause impaired strength or motion, amputation, psychiatric disorder, disabled pts., those living >80 miles away | N=26 | none--all had compartment syndrome treated by fasciotomy | none | reports of pain | 2.4 years after hospital admission (on avg.) | No | Yes | bivariate comparisons | None | Compartment syndrome treated by fasciotomy led to impaired isokinetic muscle strenght of the injured leg. No diff. Though compairing polytrauma pts. To single trauma. | Fair
Lacoux, 2002(35) | Pain in traumatic upper limb amputees in Sierra Leone | Amputation, non-veteran | Cross sectional | Included | To study stump pain, phantom sensation, and phantom pain in 40 pts post-amputation. | Study conducted in Sierra Leone - provides cross-cultural data | Non-veterans, Mean age 39.4 32 men, 8 women African | All amputees included, no exclusion criteria | N=40 | n/a | n/a | Self-reports of pain | 10–48 months after injury | Yes | Yes | bivariate comparisons | None | All pts (100%) had stump pain. 93% had phantom sensations, but phantom pain was less common (33% unilateral vs. 18% bilateral) | Poor
Millstein, 1985(36) | A review of employment patterns of industrial amputees--factors influencing rehabilitation | Amputation | Cross sectional | Included | The study investigated the current employment status of amputees and the factors that influenced successful return t work postamputation | amputee clinic at ontario worker compensation board | 95% male, age 35, 12% multiple amputations | every person with amputation a result of work related accident between 1917 and 1981 | 1010pts total (117 with multiple amputations) | n/a | n/a | presence of stump and phantom/limb pain | variable | No | yes-by multiple vs. single amputation | bivariate comparisons | Not specified | When the influence of stump and phantom limb pain was examined, the data revealed that there was a high incidence of both kinds of pain. Their incidence was reported by 63% of upper limb amputees, 74 % of lower limb ammputees and 73% of multiple level amputees. Stump and phantom limb pain were identified as variables that were negatively associated wtih successful employment as subjects reporting higher levels of pain were less likely to be working | Poor
Pezzin, 2000(37) | Rehabilitation and the long-term outcomes of persons with trauma-related amputations | Amputation, non-veteran | Cohort study, retrospective | Majority | To examine the long-term physical, social, and mental health outcomes of people who had trauma-related amputation. Also to explore factors affecting variation in outcomes and the role of inpatient rehab in improving vucntioning and well being. | Pts who underwent trauma-related amputation at 1 specific hospital between '84–'94. They were then contacted and interviewed. | Non-VA, 87% male Mean age 32.9 (10.6)at time of injury. 75% white | Inclusion - discharged from hospital between '84–'94 following trauma-related amputation. Exclusion: amputation for non-injury reasons (e.g. diabetes), spinal cord injury or TBI | N-78 | n/a | Compared their sample trauma pts to mean population scores on the SF-36. | Quality of life scores | Average of 7.5 yrs after hospital discharge | Yes | No | Mostly descriptive stats & logistic regression | None | Trauma pts had poor QOL scores for physical functioning than the general population. No sig. Diff on mental health (7.5 yrs post-injury). 25% are sig. bothered by phantom pain. Nearly all pts. (97%) working at time of injury, but only 58% working at time of the study 0 and were working in less physically demanding positions. Several factors predicted whether pt. received inpt rehab tx (40% of pts): older at time of injury, +premorbid illness, non-white ethnicity, & pts who spent more days in the ICU at time of injury. Inpt rehab significantly improved health (QOL scores) & vocational prospects (more likely to return to work). White ethnicity had better outcomes than non-white. | Fair
Roganovic, 2006(38) | Pain syndromes after missile-caused peripheral nerve lesions: part 2 treatment | Peripheral nerve injury | Cohort study--retrospective | Included | To analyze treatment procedures and painful missle-caused nerve injuries and factors influencing the outcome | single hospital in Serbia | not specified (not US patients) 90.5% male | pain syndromes related to missle trauma inclusion:nerve injury-related mechanism of pain, injury to missle, need for surgical apin treatment, and/or constant meds for >10 days exclusion : pain not related to missle-caused nerve injury | 326 | treatment differed based on type of injury | none | pain syndromes, pain intensity | varied based on procedure coducted at least one year | yes | No | univariate and multivariate stats | None | three factors predicted successful outcome: type o pain syndrome, severity of nerve injury, and absence of apin paroxysms rate of successful pain treatment differed based on pain diagnosis. Medications should be used to treat certain pain syndromes Adverse events: dizziness, nausea and /or headache(10%) in pateints treated with meds; 7.5% of pts after surgery. | Fair
Roganovic, 2006(39) | Pain syndromes after missle- caused peripheral nerve lesions: part 1---treatment | Complex regional, peripheral injury | Cohort study --- retrospective | Included | to report on the clinical characteristics of pain and factors influencing pain intensity in pts. With missle- caused nerve injuries | single hospital in Serbia | veterans/active military ---not specified (not US patients) age range, mean--12–63(mean=35.3 +/− 15, race not specified, 90% male | nerve injury--related mechanism od pain, injury two missle, need for surgical pain treatment, and/or constant meds. For >10 days | 326 | different pts. Had different interventions depending on type of injury and pain syndrome | none | pain syndromes, pain intensity | days after surgery | yes | No | univariate and multivariate stats ANOVA, kruskal-Walli, logistic regression | None | Pain syndromes caused by missles differ significantly regarding time of pain onset, pain characteristics and other symptoms. Type of pain syndrome, multiple nerve damage, and early onset of pain areindependent predictors of intial pain intensity. | Fair
Nampiaparamp il, 2008(40) | Prevalence of Chronic Pain After traumatic Brain Injury | Headache, TBI | Systematic review | Included | To determine the prevalence of chronic pain as an underdiagnosed consequence of TBI and to review the interaction between chronic pain and severity of TBI as well as the characteristics of pain after T BI among civilians and combatants. | variable | variable-systematic review, all studies observational | Three studies that met all other criteria were excluded because they focused on individuals youger than 16 years. | 23 studies, 4206 total pts. | n/a | n/a | pain prevalence | variable | yes-pain prevalence | yes-severity of TBI | pooling data by adding across studies;bivariate anlyses | --- | Twelve studies assessed headache apin in 1670 patients. Of these, 966 complained of chronic headache, yielding a prevalence of 57.8% (95% confidence interval [ CI ] 55.5%–60.2%). Among civilians, the prevalence of chronic pain was greater in patients with mild TBI (73.% [95%CI, 72.7%–77.9%])compared with moderate or severe TBI(32.1%[95%CI, 29.3%–34.9%]). twenty studies including 3289 civilian patients withTBI yielded a chronic pain prevalence of 51.5%(95% CI,49.8%–53.2%). Three studies assessed TBI among 917 verterans and yielded a pain prevalence of 43.1%(95%CI, 39.9%–46.3%). PTSD may mediate chronic pain, but brain injury appears to have an independent correlation with chronic pain. | Fair
Ulvik, 2008(41) | Quality of life 2–7 years after major trauma | --- | Cohort study-- retrospective | All | To assess the potential impairmentin HRQol in trauma patients before injury and 2–7 years after discharge from the ICU. A further objective has been to study the following parameters a possible determinants of HRQOL: age, sex, time since trauma, Simplified Acute Physiology Score (SAPS) II, injury Severity Score (ISS), and severe head injury. | Norwegian 900 bed University hospital | 81% male, average 39, mean ISS 25, 28% with sevre head injury, race-- not specified | Trauma pts admitted to ICU between 1998 and 2003 who completed flu in 2005 | 210 | n/a | n/a | EQ5D pain/discomfort | variable | No | yes-- by injury severity scores | multivariable regression | Age, sex, years since trauma, injury severity variables | --pts without severe head injury reported more problems with pain/discomfort -- years since trauma negatively associated with pain/discomfort(p=0.035) | ---
Stalp, 2002 (42) | Standardized Outcome Evaluation after Blunt Multiple Injuries by scoring Systems: A Clinical Follow-up Investigation 2 Years Injury | --- | Cohort study-- prospective | All | To evaluate the state of rehabilitation in patients with blunt multiple injuries 2 years after their initial injuries using several standardized scales. | multisite registry form 26 trauma centers in Germany | 56% men, mean age=36, mean ISS=24, mean initial GCS=11 | -- Blunt multiple injuries 2 years before follow-up investigation -- treated at level 1 trauma center | 254 | n/a | n/a | reports of pain | mean 2.2 yrs after injury | No | No | Bivariate comparisons only | None | In patients who reported restrictions of the lower extremity of. 52% indicated pain or impaired ability to walk caused by the injury to the foot and ankle, 31% to the kneee or thigh, and 17% to the femur or hip. | Fair

EVIDENCE TABLE 2 Ongoing research on pain in patients with polytrauma

Principal Investigator | Project Title | Main objective(s) of project | Study characteristics | Main outcome measures | Measures of other conditions | Project status
Afari, N. | Headaches in veterans returning from Iraq/Afghanistan: relation to trauma and combat-related injury | To determine the relationship between Post-Traumatic Stress Disorder (PTSD), TBI, self-report of headaches, and combat-related injury in Operation Endjuring Freedom (OEF) and Operation Iraqi Freedom (OIF) veterans. | Study design: Cross-sectional Population: 343 male and female veterans registering for care at the VA San Diego Healthcare System between April and October 2006 Exposures: Combat Exposure Scale, injury during combat, serious head injury, PTSD, depression, substance abuse Outcomes: Prevalence and odds ratios of headaches (tension, migraine, or both) Timing of assessment: Upon enrollment for member services | Self-report of headaches (yes,no) Self-report of diagnosis of migraines, tension headaches, or both (Yes, No) | Davidson Trauma Scale (score >=40 indicates PTSD) Combat Exposure Scale Drug Abuse Screening Test (substance abuse >=2) Self-report two-item depression screener (Yes, No) Self-report of injury during combat (Yes, No) Self-report of serious head injury (Yes, No) | Completed but no data published yet.
Bair, M. | Evaluation of Stepped CAre for Chronic Pain (ESCAPE) | To compare the effectiveness of a stepped care intervention vs. usual care in OIF/OEF veterans with chronic and disabling musculoskeletal pain and to evaluate the impact of this intervention on pain-related disability, pain severity, psychological distress, and secondary outcomes (work functioning, health-related QOL, self-efficacy to manage pain, negative pain beliefs and coping, & satisfaction with treatment). | Study design: RCT Population: 300 OIF/OEF veterans with chronic and disabling musculoskeletal pain of the spine or extremities Intervention: Stepped care approach: 1) 12wks analgesic plus self-management program 2) 12wks cognitive behavioral therapy Comparator: not specified Outcomes: pain-related disability, pain severity, psychological distress, and secondary outcomes (work functioning, health-related QOL, self-efficacy to manage pain, negative pain beliefs and coping, & satisfaction with treatment) Timing of outcome assessment: baseline, 3 mos, 6, mos, 9 mos | Roland Disability Scale; Graded Chronic Pain Scale SF-12 Bodily Pain scale; BPI Interference scale Pain Catastrophizing Scale; Pain Stages of Change Questionnaire (PSOCQ); 3-item pain-specific patient satisfaction scale; Arthritis Self-Efficacy Scale | Patient Health Questionnaire (PHQ-9) for depression; Mental Component Summary Score (MCS) derived from the SF-12; PHQ anxiety scale; PCL-17, from DSM III-R criteria for PTSD; Global Rating of Change will be used to assess overall clinical response Work and Health Interview; Medical Outcomes Study SF-12, provides both a Physical and Mental Component Summary score Patient Health Questionnaire somatic symptom severity scale (PHQ-15); Patient Health Questionnaire stressor scale | Protocol has started, some recruitment
Brandt, C. and Haskell, S. | Women Veterans Cohort Study | Aim I. To assess health care utilization, costs, and satisfaction during the complete 2 year healthcare coverage after discharge from service among female and male OEF/OIF veterans. Aim II. To assess changes in healthcare utilization, costs and satisfaction after the 2-year complete healthcare coverage ends. Aim III. To compare the diagnosis and treatment of stress associated conditions during the 2-year complete healthcare coverage | Study design: prospective cohort based on survey data Population: OEF/OIF veterans recruited from 5 VA Medical Centers Exposure: during 2-yr complete health coverage after discharge Comparator: after the 2-yr coverage ends Survey of healthcare ustilization, cost, satisfaction post-discharge, before and after 2-yr health coverage Outcomes: healthcare utilization, cost, satisfaction, stress, and pain scores Timing of assessment: baseline and every 12 months for 3+ years | Brief Pain Inventory; VR-12; Veterans Health Survey pain care satisfaction | Combat Exposure scale, PCL and Trauma Questionnaire (PTSD), PRIME-MD. | Awaiting confirmation of funding for additional sites. Hoping to start national data work and survey work at 2 sites 3/08.
Clark, M.E. | Pain and Emotional Disorders in Veterans with and without Polytrauma | a) Describe the prevalence, types, and course of pain and psychiatric disorders among patients with and without polytraumatic injuries; b) Determine whether patients with polytrauma have unique pain-related or emotional problems compared to OEF and OIF returnees registered for VA care but without polytrauma; c) Identify risk factors for the development of chronic pain and emotional disorders in these cohorts; d) Determine the interaction of emotional disorder comorbidities with pain or emotional symptom severity; and e) Describe the functional outcomes, associated disabilities, and community reintegration challenges associated with pain and emotional disorders among OEF/OIF service members with and without polytrauma. | Study design: prospective cohort using structured interviews Population: OEF/OIF military personnel; cross-sectional samples of 150–200 polytrauma and 300–400 non-polytrauma OEF/OIF military personnel from two sites (Minneapolis and Tampa VAs) Exposure: Polytrauma patients Comparator: Veterans without polytrauma Outcomes: Prevalence of pain and psychiatric disorders; risk factors for the development of chronic pain and emotional disorders; effect of emotional disorder comorbidities on pain; functional outcomes and disabilities. Sub-studies will be used to validate a new measure of deployment stress exposure, assess VA pain and emotional treatment satisfaction, determine 12-month incidence of new-onset pain and mental health problems, and evaluate the frequency and type of non-VA medical service utilization among OEF/OIF medical care registrants. Timing of assessment: baseline, 6 mo, 12 months | Military Hx; Pain Hx; MH Hx; Pain Dx; Pain Intensity; Pain-related interference (POQ); CPCI; CPQ; FABQ; STAI; CES-D; sleep measure (SPQ); fatigue measure (MFSI-SF); relationship measure (DAS-SF). | Psychiatric Dx via structured interview (M.I.N.I.); VA PTSD screen; CAGE; Blast exposure; medical Dx; depression and anxiety as above. | Approved; funded; still waiting HSR&D disbursement of 1st-years funds.
Gallagher, R. | Regional Anesthesia Military Battlefield Pain Outcomes Study | 1) Quantify and characterize short-term and long-term effects traumatic extremity injuries during combat on post-injury pain, health-related quality of life (HRQOl), functional status, social reintegration, psychological adjustment and substance abuse among returning Iraq/Afghanistan veterans 2) Evaluate the efficacy of early aggressive advanced regional anesthetic interventional techniques on neuropathic pain, HRQOL, and mental health disorders among soldiers at 2-yrs post-injury | Study design: prospective cohort study based on medical records and interviews Population: OEF/OIF soldiers with one or more maligned or amputated limbs Exposure: traumatic extremity injuries Intervention: early aggressive advanced regional anesthetic techniques Outcome: pain, health-related QOL, functional status, social reintegration, psychological adjustment, substance abuse Timing of outcome assessment: baseline and 2-yrs post injury | 1) TOPS (Treatment Outcomes in Pain Survey) 2) BPI 3) Neuropathic Pain Scale 4) Behavioral Health Laboratory Inventory 5) Injury Severity Index 6) Post-discharge treatment | Depression, PTSD, Substance Abuse | In progress
Gironda, R.J. | Chronic Headache among OEF/OIF Veterans Exposed to Blasts | The purpose of the current study is to provide an initial evaluation of the clinical characteristics and treatment of headache conditions among OEF/OIF veterans who have been exposed to blasts during deployment. Is brief cognitive-behavioral headache management treatment (BCBHMT) feasible and effective for the reduction of blast-related headache frequency and associated disability? | Study design: case series Population: OEF/OIF veterans referred to the JAHVH PRC Blast Injury Clinic (Tampa) Intervention: cognitive-behavioral headache management treatment (BCBHMT) Outcomes: changes in headache severity and duration, unctional disability, and health-related quality of life; PTSD symptoms; sleep problems; fatigue symptoms; Timing of outcome assessment: Baseline and 3 months | McGill Pain Questionnaire; Headache Disability Index; CES-D; STAI- State scale; Multidimensional Fatigue Symptom Inventory (Short Form); Sleep Problems Questionnaire; PTSD Symptoms Checklist Military Version; RBANS | CES-D; STAI-State scale; Multidimensional Fatigue Symptom Inventory (Short Form); Sleep Problems Questionnaire; PTSD Symptoms Checklist Military Version; RBANS | Recruitment has begun.
Helmer, D. | Pain, mental health, and daily function in OIF/OEF veterans | To describe the pain concerns of OIF/OEF veterans, examine the association between pain and comorbid mental health concerns, and model the impact of these concerns on daily functioning. | Study design: cross-sectional, retrospective review of self-administered clinical intake/screening data Population: The first 233 OIF/OEF veterans with complete data evaluated at the War-Related Illness and Injury Study Center (WRIISC) in East Orange, NJ (June 2005-August 2007) Outcomes: Pain, mental health comorbidity, daily functioning Timing of outcome assessment: at time of clinical intake/screening | Veterans RAND (VR)-36 Bodily Pain (BP) and Role Physical (RP) scales; chronic widespread pain (CWP) | 1) Patient Health Questionnaire (PHQ) 2) Post-traumatic stress disorder (PTSD), depression, and problem alcohol use screening instruments (AUDIC-C). | Completed but no data published yet.
Kerns, R. | Pain Assessment in Polytrauma Rehabilitation Centers (PRCs) | Evaluate usability and utility of CPRS pain assessment templates in two PRC sites, modify education materials in support of these templates, and develop and pilot pain reports for clinicians based on these templates. [underlined: Secondary objectives are to develop a pain assessment database and identify best practices for pain care in this patient population]. | Study design: Qualitative and quantitative information collected from clinicians Population: Providers and nursing staff in two PRCs (Minneapolis and Tampa). Intervention: The pain template contains modules designed for initial comprehensive assessment and reassessment of pain. Outcomes: Pain intensity, pain quality, pain location, alleviating and aggravating factors, medication use, and pain-related disability including mood, sleep, physical activity, sleep and work Timing of outcome assessment: Physicians and nurses are encouraged to comprehensively assess all new patients when they present to the PRC. | Measures included in the templates themselves which are pain intensity (NRS 0–10 scale), pain quality, pain location, alleviating and aggravating factors, medication use, and pain-related disability including mood, sleep, physical activity, sleep and work. | The pain template contains a module designed to assist clinicians in evaluating pain in patients with cognitive impairment. The template does not explicitly collect data regarding the nature or magnitude of the impairment, but does provide support for collecting accurate pain assessments in the context of cognitive impairment. | The project has been approved and is in progress.
Lawrence, V.A. | Long-term Outcomes in Burned OEF/OIF Veterans (LOBO) | To assess long term outcomes in OEF/OIF veterans with combat burn injury, combat nonburn injury, and in a 3rd cohort of civilian burn patients | Study design: Prospective cohort Population: OEF/OIF veterans with a combat burn injury, combat nonburn injury, and civilian burn patients Exposure groups: burn injury, non-burn injury; combat veterans, civilians Outcomes: PTSD, depression, sleep Timing of outcome assessment: Baseline, 1, 2, 3, and 4 years. | McGill Pain Questionnaire – Short Form SF-12 | PCL-C and M (PTSD), CES-D (Depression), Epworth sleepiness scale. AUDIT-C | In progress
Lew, H. | Characterization and Care Coordination of Polytrauma Patients | To study & describe characteristics of polytrauma patients, including the nature and severity of cognitive, emotional, physical and overall functional impairment. | Study design: Cross-sectional Population: OIF/OEF patients injured by explosive devices or blasts Exposure groups: blast injury alone; blast TBI; non-blast TBI; PTSD; non-PTSD Outcomes: nature and severity of cognitive, emotional, physical and overall functional impairment. Timing of outcome assessment: clinic visit | VAS | PTSD (PCL) Memory Loss/Cognition (Neuropsych measures) | in progress.
Lew, H. | Clinical Characteristics of Patients with Polytrauma and Blast-Related Injuries | To describe the clinical characteristics, interventions and outcomes for inpatients with polytrauma and blast-related injuries treated through the Polytrauma Rehabilitation Center (PRC) at the VAPAHCS. | Study design: retrospective review of routine care data Population: veterans who were inpatients at the 4 PRCs. Exposure: polytrauma and blast-related injuries Outcomes: clinical characteristics, interventions; sleep disturbances, post-concussive symptoms, combat-related stress, functional independence | Per medical record | Sleep disturbances, post-concussive sx, combat-related stress, FIM | Ongoing—some preliminary findings
Lew, H. | Predicting Rehabilitation Costs for VA Patients with Traumatic Brain Injury | To estimate cost of care for a sample of TBI patients. Objectives include: 1) To determine differences, if any, in cost patterns for rehabilitation among OEF/OIF returnees with combat-related TBI versus those with non-combat related TBI 2) To compare the utility of Life Care Planning and FIM scores in predicting total rehabilitation costs fro the same period. 3) To examine how PTSD impacts future outcomes and costs associated with combat-related TBI. | Study design: retrospective cohort study Population: a sample of OEF/OIF patients with TBI, physical injury, and emotional trauma, discharged from the PRC, and treated at the Palo Alto and Tampa VA Exposure groups: Combat-related TBI, non-combat TBI; PTSD Outcomes: Cost of care for rehabilitation; utility of Life Care Planning and FIM scores for predicting cost of care Timing of outcome assessment: Up to 12 months after initial discharge | Functional Independence Measure. VAS | PTSD (PCL), Costs, Cognitive status (neuropsych data) | Ongoing
Roy M.J. | The ViRTICo Trial: Virtual Reality Therapy & Imaging in Combat Veterans | 1. Distinguish between four groups of 22 GWOT veterans each, those with: PTSD and TBI combined; PTSD alone; TBI alone; and neither PTSD nor TBI, using an Affective Stroop test as well as digital photographs taken in Iraq and Afghanistan, in conjunction with functional magnetic resonance imaging (fMRI). 2. Demonstrate that VRET is non-inferior to the current first-line therapy for which there is best evidence, Prolonged Exposure (PE), in the treatment of OIF/OEF combat veterans with PTSD. | Study design: controlled clinical trial Population: Global War on Terror (GWOT) veterans with PTSD and TBI combined; PTSD alone; TBI alone; and neither PTSD nor TBI. Intervention: Virtual Reality Exposure Therapy & Imaging Comparator: Prolonged exposure (current first-line therapy). Outcomes: functional health and disability - 6 domains: understanding and communicating, getting around, self care, getting along with others, household and work activities, participation in society Timing of outcome assessment: Baseline (following assessment at Walter Reed); post-treatment; 12-week follow up | SF-36 World Health Organization Disability Assessment Schedule – II (WHODAS-II) | The primary outcome measure for judging success will be a 30% reduction in CAPS score at the end of treatment. Additional outcome measures will include a 30% reduction in CAPS scores at the end of a 12-week follow up period, significant reductions in scores on measures of other psychiatric disorders such as anxiety and depression, and a significant reduction in associated functional impairment at these endpoints on the SF-36 and WHODAS-II. | In progress
Siddharthan, K. | Telerehabilitation of OEF/OIF combat wounded with TBI | To provide for care coordination and monitor functional and cognitive outcomes of 45 veterans treated and discharged from the James Haley Veterans Hospital in Tampa, FL with combat related TBI | Study design: cohort Population: Veterans with combat related TBI Exposure: Pain medications Outcomes: Adverse effects of pain medication on functional and cognitive outcomes (withdrawal symptoms/suicidal tendencies/addiction/accidents, etc.) | FIM/FAM and CHART for community Integration | Effects of drug therapy for pain management on cognitive deficits and mental health. | In progress
Storzbach, DM | Multidiscipline Assessment of Blast Victims for Cognitive Rehabilitation | To determine whether blast exposure during military service is associated with increased risk for neuropsychological deficits and/or psychiatric disorder, and to determine whether blast-related symptoms of post-concussive syndrome are caused by the psychiatric effects of the wartime environment, neuropsychological effects of traumatic brain injury, or sub-optimal motivation. | Study design: prospective cohort Population: OEF/OIF veterans in one of 3 exposure groups Exposure groups: 1) explosion-exposed and reports <= 0.5 hour loss of consciousness, or <=24 post-traumatic amnesia following the explosion(s); 2) explosion-exposed without subsequent symptoms of concussions; 3) Unexposed to explosions Outcomes: neuropsychological deficits and psychiatric disorder Timing of outcome assessment: 1 assessment visit; 1st participant enrolled 4/29/08, expected to continue at least through 8/09. | Pittsburgh Sleep Quality Index (PSQI; Buysse et al., 1989); • British Columbia Post Concussive Symptom Inventory (BC-PSI; Iverson, 2005); Ruff Neurobehavioral Inventory: Cognition, Pain, Work Questionnaire (RNBI: CPW; Ruff & Hibbard, 2003); Test of Memory Malingering (TOMM; Tombaugh, 1996); PTSD Checklist; Military Version (PCL - M; Weathers & Ford, 1996); Personality Assessment Inventory (PAI; Morey, 1991) | Ruff Neurobehavioral Inventory: Cognition and Work Questionnaire (RNBI: CPW) | In progress
Walker, R.L. | Evaluation of Polytrauma Pain | The primary objective of this study is to retrospectively examine the pain experiences of those soldiers and veterans who have incurred polytraumatic injuries during Operation Iraqi Freedom/Operation Enduring Freedom (OIF/OEF) conflicts. | Study design: retrospective chart review Population: OIF/OEF veterans with polytrauma injuries and were treated at the JAHVH-PRC between 2003–2006. Exposures: Nature, extent, and treatment of polytrauma injuries (on admission) Outcomes: Previous pain treatment (before admission); level of cognitive functioning (at admission and discharge); pain intensity scores (at admission and discharge); diagnose(s); pain location(s) (at admission and discharge); pain duration; pain management/interventions utilized during rehabilitation; pain management consult(s) initiated; co-morbid emotional symptoms and treatments provided Timing of outcome assessment: indicated in outcomes, above | Per medical record | The only measure of cognitive functioning that was collected in this study was the patients’ Rancho score that was assigned by the treating team upon admission and discharge. Data regarding psychological diagnoses was collected, along with information on what type of psychological (or psychiatric) treatment was conducted during rehabilitation. | The data has been collected for this project, but only portions of the data have been published up to this point in time.
Walker, W. | Concurrent Validity of Four Pain Intensity Scales in persons with Polytrauma and Cognitive Impairment | A preliminary analysis to examine the concurrent validity of four pain intensity scales in the traumatic brain injury (TBI) inpatient rehabilitation population. | Study design: prospective randomized measurement study Population: 15 consecutive adult patients who were admitted for acute rehabilitation within 12 months of major trauma, who reported pain initially, and consented to participate Interventions: pain assessment; memory assessment Outcomes: Current pain on days 0, 3, 7, 10, & 14; vividly remembered “worst pain ever” on Day 0 and 14 Timing of outcome assessment: Days 0, 3, 7, 10, & 14 | Faces pain scale, verbal descriptor scale (VDS), color analogue scale (CAS) and numerical (0–10) box-scale (BS-11) | Memory Orientation & Amnesia Test | In progress. As of March 13, “The study is ongoing with a recruitment goal of 60 subjects.”
Widerstrom-Noga, E. | Validity and reliability of proton magnetic resonance spectroscopy as a diagnostic and outcome measure in clinical pain trials involving people with spinal cord injury. | The present study will determine the validity and reliability of Magnetic Resonance Spectroscopy (MRS) as a diagnostic and outcome measure for clinical trials involving SCI chronic pain populations. The long-term goal of our pain research is to improve the management of chronic neuropathic pain following SCI. | Study design: measurement study Population: 60 persons with SCI and chronic neuropathic pain, 25 persons with SCI without neuropathic pain, and 25 able-bodied control subjects Intervention: Magnetic Resonance Spectroscopy (MRS) Outcomes: Pain, functioning, and mood; neurological examinations and MRS imaging procedures Timing of outcome assessment: 2–4 weeks after 1st session (baseline screening); additionally, 2–4 weeks after 1st session for SCI patients with neuropathic pain. | Medical History and Demographic questionnaire Pain History Form Multidimensional Pain Inventory (MPI) Numerical Rating Scales (NRS) | Functional Independence Measure (FIM) Craig Handicap Assessment and Reporting Technique (CHART) Spielberger State-Trait Anxiety Inventory (STAI) Coping Strategies Questionnaire (CSQ) Beck Depression Inventory (BDI) Structured interview to rule out major psychiatric illness and major depression Folstein Mini-Mental Status Examination to screen out traumatic brain injury | Ongoing

## References in Evidence Table 1

1 Bay E, Donders J. Risk factors for depressive symptoms after mild-to-moderate traumatic brain injury. Brain Inj. 2008;22(3):233-41. [pmid: 18297595].
2 Beetar JT, Guilmette TJ, Sparadeo FR. Sleep and pain complaints in symptomatic traumatic brain injury and neurologic populations. Archives of Physical Medicine & Rehabilitation. 1996;77(12):1298-302. [pmid: 8976315].
3 Brenner C. Post-traumatic headache. J Neurosurgery. 1944;1:379-391.
4 Bryant RA, Marosszeky JE, Crooks J, Baguley IJ, Gurka JA. Interaction of posttraumatic stress disorder and chronic pain following traumatic brain injury. Journal of Head Trauma Rehabilitation. 1999;14(6):588-94. [pmid: 10671704].
5 Bushnik T, Englander J, Wright J. The Experience of Fatigue in the First 2 Years After Moderate-to-Severe Traumatic Brain Injury: A Preliminary Report. The Journal of head trauma rehabilitation. 2008;23(1):17-24. [pmid: 18219231].
6 Cantor JB, Ashman T, Gordon W, Ginsberg A, Engmann C, Egan M, et al. Fatigue after traumatic brain injury and its impact on participation and quality of life. The Journal of head trauma rehabilitation. 2008;23(1):41-51. [pmid: 18219234].
7 Cosgrove JL, Vargo M, Reidy ME. A prospective study of peripheral nerve lesions occurring in traumatic brain-injured patients. American Journal of Physical Medicine & Rehabilitation. 1989;68(1):15-7. [pmid: 2917053].
8 Dawson DR, Schwartz ML, Winocur G, Stuss DT. Return to productivity following traumatic brain injury: cognitive, psychological, physical, spiritual, and environmental correlates. Disability & Rehabilitation. 2007;29(4):301-13. [pmid: 17364780].
9 Guttman E. Postcontusional Headache. Lancet. 1943;1:10-12.
10 Hillier SL, Sharpe MH, Metzer J. Outcomes 5 years post-traumatic brain injury(with further reference to neurophysical impairment and disability). Brain Injury. 1997;11(9):661-75. [pmid: 9376834].
11 Hoffman JM, Pagulayan KF, Zawaideh N, Dikmen S, Temkin N, Bell KR. Understanding pain after traumatic brain injury: impact on community participation. American Journal of Physical Medicine & Rehabilitation. 2007;86(12):962-9. [pmid: 18090437].
12 Lippert-Gruner M, Maegele M, Haverkamp H, Klug N, Wedekind C. Health-related quality of life during the first year after severe brain trauma with and without polytrauma. Brain Inj. 2007;21(5):451-5. [pmid: 17522984].
13 Masson F, Maurette P, Salmi LR, Dartigues JF, Vecsey J, Destaillats JM, et al. Prevalence of impairments 5 years after a head injury, and their relationship with disabilities and outcome. Brain Injury. 1996;10(7):487-97. [pmid: 8806009].
14 Olver JH, Ponsford JL, Curran CA. Outcome following traumatic brain injury: a comparison between 2 and 5 years after injury. Brain Injury. 1996;10(11):841-8. [pmid: 8905161].
15 Walker WC, Seel RT, Curtiss G, Warden DL. Headache after moderate and severe traumatic brain injury: a longitudinal analysis. Archives of Physical Medicine & Rehabilitation. 2005;86(9):1793-800. [pmid: 16181945].
16 Brenneman FD, Katyal D, Boulanger BR, Tile M, Redelmeier DA. Long-term outcomes in open pelvic fractures. Journal of Trauma-Injury Infection & Critical Care. 1997;42(5):773-7.
17 Hebert JS, Burnham RS. The effect of polytrauma in persons with traumatic spine injury. A prospective database of spine fractures. Spine. 2000;25(1):55-60. [pmid: 10647161].
18 Tran T, Thordarson D. Functional outcome of multiply injured patients with associated foot injury. Foot & Ankle International. 2002;23(4):340-3. [pmid: 11991481].
19 Turchin DC, Schemitsch EH, McKee MD, Waddell JP. Do foot injuries significantly affect the functional outcome of multiply injured patients?. Journal of Orthopaedic Trauma. 1999;13(1):1-4. [pmid: 9892116].
20 Urquhart DM, Williamson OD, Gabbe BJ, Cicuttini FM, Cameron PA, Richardson MD, et al. Outcomes of patients with orthopaedic trauma admitted to level 1 trauma centres. ANZ Journal of Surgery. 2006;76(7):600-6. [pmid: 16813626].
21 Zelle BA, Brown SR, Panzica M, Lohse R, Sittaro NA, Krettek C, et al. The impact of injuries below the knee joint on the long-term functional outcome following polytrauma. Injury. 2005;36(1):169-77. [pmid: 15589937].
22 Anke AG, Stanghelle JK, Finset A, Roaldsen KS, Pillgram-Larsen J, Fugl-Meyer AR. Long-term prevalence of impairments and disabilities after multiple trauma. Journal of Trauma-Injury Infection & Critical Care. 1997;42(1):54-61.
23 Brenneman FD, Redelmeier DA, Boulanger BR, McLellan BA, Culhane JP. Long-term outcomes in blunt trauma: who goes back to work?. J Trauma. 1997;42(5):778-81. [pmid: 9191655].
24 Dimopoulou I, Anthi A, Mastora Z, Theodorakopoulou M, Konstandinidis A, Evangelou E, et al. Health-related quality of life and disability in survivors of multiple trauma one year after intensive care unit discharge. American Journal of Physical Medicine & Rehabilitation. 2004;83(3):171-6. [pmid: 15043350].
25 Fitzharris M, Fildes B, Charlton J, Kossmann T. General health status and functional disability following injury in traffic crashes. Traffic Injury Prevention. 2007;8(3):309-20. [pmid: 17710722].
26 Holtslag HR, van Beeck EF, Lindeman E, Leenen LPH. Determinants of long-term functional consequences after major trauma. Journal of Trauma-Injury Infection & Critical Care. 2007;62(4):919-27.
27 MacKenzie EJ, Morris JA Jr, Jurkovich GJ, Yasui Y, Cushing BM, Burgess AR, et al. Return to work following injury: the role of economic, social, and job-related factors. Am J Public Health. 1998;88(11):1630-7. [pmid: 9807528].
28 Meerding WJ, Looman CW, Essink-Bot ML, Toet H, Mulder S, van Beeck EF. Distribution and determinants of health and work status in a comprehensive population of injury patients. J Trauma. 2004;56(1):150-61. [pmid: 14749582].
29 Mkandawire NC, Boot DA, Braithwaite IJ, Patterson M. Musculoskeletal recovery 5 years after severe injury: long term problems are common. Injury. 2002;33(2):111-5. [pmid: 11890911].
30 Soberg HL, Bautz-Holter E, Roise O, Finset A. Long-term multidimensional functional consequences of severe multiple injuries two years after trauma: a prospective longitudinal cohort study. Journal of Trauma-Injury Infection & Critical Care. 2007;62(2):461-70.
31 Vles WJ, Steyerberg EW, Essink-Bot ML, van Beeck EF, Meeuwis JD, Leenen LP. Prevalence and determinants of disabilities and return to work after major trauma. J Trauma. 2005;58(1):126-35. [pmid: 15674163].
32 Dougherty PJ. Long-term follow-up study of bilateral above-the-knee amputees from the Vietnam War. Journal of Bone & Joint Surgery - American Volume. 1999;81(10):1384-90.
33 Dougherty PJ. Transtibial amputees from the Vietnam War. Twenty-eight-year follow-up. Journal of Bone & Joint Surgery - American Volume. 2001;83-A(3):383-9.
34 Frink M, Klaus A-K, Kuther G, Probst C, Gosling T, Kobbe P, et al. Long term results of compartment syndrome of the lower limb in polytraumatised patients. Injury. 2007;38(5):607-13. [pmid: 17306263].
35 Lacoux PA, Crombie IK, Macrae WA. Pain in traumatic upper limb amputees in Sierra Leone. Pain. 2002;99(1–2):309-12. [pmid: 12237209].
36 Millstein S, Bain D, Hunter GA. A review of employment patterns of industrial amputees--factors influencing rehabilitation. Prosthetics & Orthotics International. 1985;9(2):69-78. [pmid: 4047922].
37 Pezzin LE, Dillingham TR, MacKenzie EJ. Rehabilitation and the long-term outcomes of persons with trauma-related amputations. Archives of Physical Medicine & Rehabilitation. 2000;81(3):292-300. [pmid: 10724073].
38 Roganovic Z, Mandic-Gajic G. Pain syndromes after missile-caused peripheral nerve lesions: part 2--treatment. Neurosurgery. 2006;59(6):1238-49. discussion 1249–51. [pmid: 17277686].
39 Roganovic Z, Mandic-Gajic G. Pain syndromes after missile-caused peripheral nerve lesions: part 1--clinical characteristics. Neurosurgery. 2006;59(6):1226-36. discussion 1236–7. [pmid: 17277685].
40 Nampiaparampil DE. Prevalence of chronic pain after traumatic brain injury: a systematic review. JAMA. 2008;300(6):711-9. [pmid: 18698069].
41 Ulvik A, Kvale R, Wentzel-Larsen T, Flaatten H. Quality of life 2–7 years after major trauma. Acta Anaesthesiologica Scandinavica. 2008;52(2):195-201. [pmid: 18005377].
42 Stalp M, Koch C, Ruchholtz S, Regel G, Panzica M, Krettek C, et al. Standardized outcome evaluation after blunt multiple injuries by scoring systems: a clinical follow-up investigation 2 years after injury. Journal of Trauma-Injury Infection & Critical Care. 2002;52(6):1160-8.