# REVIEWER COMMENTS AND RESPONSES

Reviewer | Comment | Response
Question 1. Are the objectives, scope, and methods for this review clearly described?
Bair | yes | Noted
Buffum | Overall, this synthesis is very well-written and comprehensively addresses the clearly stated key questions. The scope is slightly confusing because content from two citations contradict the exclusion criteria. Methods are clear. Exclusions:; - Battlefield/emergent assessment and care (regional anesthesia being studied by Gallagher #120 covers battlefield.) Rehabilitation needs to be defined in terms of time frame or activities.; - Post-traumatic/post-concussive headache unrelated to blast injury unless the sample includes patients with moderate or greater cognitive deficit. (Lew #59 reviews 5 studies about TBI but not related to blast, and cognitive impairment is not mentioned in the review. Pg 16 line 28) | We have clarified that we excluded studies describing outcomes only within 3 months of injury. Studies examining longer term outcomes of non-specific surgical treatments were included. We agree that the Lew study does not meet criteria for inclusion with main findings because it does not include studies specifically including patients with blast- related headache (or according to severity of TBI.
Clark | yes | Noted
Sayer | Objectives very clear. You may want to consider dividing KQ1 into part A and B. | Noted
Sayer | Scope/Methods: There is lack of clarity with regard to scope and methods due to the heterogeneity of polytrauma both in terms of injury constellations and injury etiology and presentation of methods and findings with regard to the composition of the samples included in the research reviewed. Below I list some specific areas where further clarification with regard to sample composition (e.g., “Polytrauma”) would be helpful: see items a- f below | Noted
Sayer | a) There appears to have been inconsistency between stated study inclusion criteria (articles/research focused on pain resulting from polytraumatic injuries) and articles that were reviewed (e.g., TBI, causalgia, amputation without other injuries, blast-related headache without Polytrauma, orthopedic injuries, patients with “major trauma”). The phrase “polyrauma including TBI” is confusing to me. Do you mean that TBI = Polytrauma or that the patients had TBI that occurred in the context of other injuries. Similarly, not clear to me whether causalgia is classified as Polytrauma or whether patients with causalgia had other injuries. Does traumatic amputation = Polytrauma for the purpose of this review? | TBI of moderate to severe severity was considered polytrauma for this review, the rationale being that patients suffer from the traumatic injury itself as well as associated cognitive sequellae. Causalgia in and of itself does not meet criteria for polytrauma but as the cases included in the systematic study predominantly suffered from war-related injuries, we had included this study. However, upon further review, we feel that there is insufficient documentation in this review to consider it among the main findings, and include the results with secondary findings. Patients with unilateral injuries without evidence of other injuries were not considered to have polytrauma. Bilateral amputation was considered polytrauma in our review.
Sayer | b) Not clear on p.3 why excluding burn injuries from review. Also seems that you include burn injury in review of active research (LOBO). This is probably just a matter of clarification. | Our statement about excluding burn injuries led to confusion (and was actually not necessary). The exclusion of studies of perioperative care and surgical care encompasses the exclusion of acute treatment of burn injuries. We did not exclude studies of burn patients that examined pain related outcomes beyond perioperative care/acute burn management. We have amended the methods section accordingly.
Sayer | c) not clear to this reviewer that articles in Table 1 included patients with Polytrauma according to VA definition | TBI of moderate to severe severity is defined as polytrauma for this review. These cases studies involved patients with moderate to severe TBI or TBI concurrent with another injury/condition. Because they are case studies, these are considered secondary findings. the Table title has been changed and a footnote has been added to clarify the above.
Sayer | d) I strongly suggest being specific with regard to sample type rather than using the general terms like “patients” or “Polytrauma patients” when summarizing findings. Given the heterogeneity of Polytrauma the term loses its usefulness for literature review purposes. For example, the summary statement on p22 would be much clearer and useful if you were specific as to sample composition. | Due to the heterogeneity of the study samples, it would be challenging to describe details of each of the included studies. However, throughout the text, we have expanded the brief descriptions of samples.
Sayer | There is also some lack of clarity with regard to definition of pain related outcomes (KQ4). I do not understand reason for inclusion of psychosocial factors p 22 in context of this reviews. This is probably just a matter of clarification. | The sponsors of this review and expert panel were interested in relationships between psychosocial factors and pain-related outcomes pain intensity and pain-related disability or interference. In this review, psychosocial factors generally constitute the independent variables, and pain-related outcomes, the dependent variables. We have rewritten these sections to make this clearer.
Sayer | Other areas needing clarification and/or suggestions: a) I think you need a definition of Polytrauma that is true to your methods in the Executive Summary. | We have clarified that in addition to our main findings regarding studies that include patients meeting polytrauma criteria, we also included additional, secondary findings that may have relevance for readers of the report.
Sayer | b) I would suggest renaming Table 1 so that it is clear that it presents studies relevant to secondary findings. | See comment above. We have relabeled Table 1.
Sayer | c) I found summary of secondary findings for KQ4 confusing. I am not sure what is meant by “severity of TBI and prevalence of pain”. Do you mean “presence of pain”? I was also confused by summary statement (p.18) which focuses on mild TBI. Perhaps the focus in on association between mild TBI and pain? | We have clarified that studies focusing only on mild TBI are not included in this review. We prefer the term “prevalence” to indicate the frequency of an outcome at a given point in time; some authors of included studies use the term presence instead, which in most cases, appears to indicate the same construct. We have removed the term presence when possible.
Sayer | d) not clear why you are grading the qualitative study (p.24) given your grading criteria (p.6). | The qualitative study is not given a formal grade. It is the body of evidence for Key Question 5 that was given a formal grade. We now believe that based on only one qualitative study, we should not assign a grade for the body of evidence supporting this Key Question.
Sayer | e) I suggest adding a reference following the statement “pain is an almost universal component of poltyrauma… | We have revised this section, and it no longer contains the statement cited.
Sayer | f) I am not sure of your use of the term “emergent”. Perhaps OK, but I suggest confirming with trauma experts. | We have replaced the term emergent with the term “emergency”. We excluded studies that only measure outcomes less than 3 months after injuries.
Schreiber | yes. 3156 citations were initially identified for review and 482 articles were retrieved. Although the authors have stated their criteria for retrieving articles, it would be helpful if they cited the reasons for excluding articles specifically. For instance, how many articles were excluded because they didn’t address polytrauma patients. Similarly 482 articles were retrieved but 102 articles were included. Once again, it would be helpful if the authors specified the reasons for exclusion. For instance, how many articles were excluded because the full text could not be obtained or because the article was written in a foreign language? | We have updated the literature flow diagram in the report to contain more detail on the number of excluded articles and the reasons for exclusion.
Walker, RL | Yes, although as is described by the review committee, there was a significant challenge in finding good quality research regarding this topic in the literature. | Noted
Kerns | Yes. Although I am impressed with the effort to identify “active research” projects, I wonder if there is a potential for bias in any of several directions related to this search. For example, how extensive was the effort to identify investigators who might either be conducting relevant research or know of someone who is? Is there a potential bias in terms of identifying research involving persons representing certain disciplines (i.e., psychologists, primary care providers) relative to others (nurses, anesthesiologists, epidemiologists)? Was an active decision made not to make an effort to identify NIH, DoD, research foundation, or industry funded projects? Could a broader search still be accomplished, and if so, could it lead to identification of completed, but not reported, data and/or other ongoing active projects? | This is an important concern, and is addressed in a separate active research limitations section. We did attempt to identify relevant DOD studies, sending email inquires to a number of non-VA, including DOD, investigators. We additionally searched several VA and non-VA website databases: (National Institutes of Health Clinical Trials data base (http:www.clinicaltrials.gov), the Computer Retrieval of Information on Scientific Projects (CRISP) database, Current Controlled Trials (http://www.controlled-trials.com/mrct/), and the VA HSR&D website (http://www.hsrd.research.va.gov/research/default.cfm). We have included more informationo about our search strategies and email contacts in the report.
Question 2. Is there any indication of bias in our synthesis of the evidence?
Bair | no | Noted
Buffum | Probably not bias: Question 1 needs some clarity in defining cognitive impairment. Cognitive impairment early in rehab is not differentiated from acute…the emphasis seems to be more on chronic but it is not differentiated. Also, cognitive impairment in dementia needs more distinction for pain reporting. (pg 11 lines 3–4). Is there an MMSE cutoff where patients cannot self-report reliably? (this differs by author and is biased for language and education so doesn’t apply to everyone) If dementia is categorized as mild or moderate, that might help….most patients within these categories can understand (but not all). | Detailed exploration of these complex issues is beyond the scope of this review, especially as this section presents secondary findings from the review. We have shortened this section. We have clarified some of the statements with regard to patients having mild to severe levels of dementia.
Buffum | Pg 11 lines 14–20: there are actually 4 reviews now (2 international–Zwakhalen et al, 2006 and vanHerk et al, 2007) and (2 U.S.–Herr et al, 2006 and Stolee et al, 2005). Stolee, Herr, and vanHerk state the Discomfort Scale is most psychometrically sound (and Herr adds NOPPAIN). Zwakhalen and vanHerk refer to the PACSLAC as being bezst. Only van Herk says PAINAD is promising, and Herr says this about PACSLAC. So, it might be fair to say that there are U.S. and international differences. And the synthesis is correct that there is no one best tool! Additionally, it might be beneficial to state that multiple methods are best for assessment….which address all of the items mentioned in lines 17–20. Cohen-Mansfield’s 2008 article addresses the notion that multiple methods may be better than any single tool. Reviews of tools concur that most are tested in few studies, studies are small, not all patients have all behaviors, and new tools tend to be developed before old ones are tested. Newer tools seem to address better pain intensity, function, activity when pain behaviors are noted, and effect of specific intervention. | We have updated this section. We have reviewed the suggested manuscripts and incorporated their findings. See response above for more information.
Buffum | Also, it might be helpful to indicate that the tools for geriatrics (dementia) are rated on how well they adhere to the American Geriatrics Society Guidelines. Similar guidelines are not available specifically for TBI but other populations and issues are addressed in the ASPMN statement: Herr K. Pain assessment in the nonverbal patient: position statement with clinical practice recommendations. Pain Manage Nurs. 2006;7(2):44–52. | See above two responses.
Clark | Not bias, but some misleading statements or conclusions: a. P. 12, lines 18–20, as well as this entire section, does not address the issue of the transient effects of these treatments. In fact, the “94% …were cured” statement, which I’m sure comes from the article itself, is highly, highly unlikely since even a “successful” sympathectomy typically does not “cure” pain in that, on average, pain recurs within an 8 to 14 month period (there are numerous studies examining long-term effects of sympathectomies in the literature, including a recent Cochrane review). In fact, the use of this treatment for neuropathic pain is controversial. Blocks (rather than destruction) also are temporary, when they work at all, and endless repeat blocks or ESIs (a common practice) have other potential risks (see recent Neurology review and guidelines). | Due to questions about whether the studies included in this review clearly include patients with polytrauma, we now consider this study’s findings to be secondary findings. We have added an additional statement noting the limitations of this study’s findings.
Clark (Continued) | My point here is that I think it would be unwise to leave the reader with the impression that these procedures are all that efficacious or even, in some cases, recommended, and that effectiveness proof requires not only high quality RCTs but also temporal follow up to determine the stability of the effects | See above response.
Clark | b. On p. 15, lines 6–32, were these patients assessed for other kinds of pain beyond headaches? The last sentence reports that PTSD and depression were identified as mediators (or should they be moderators?) of physical health problems rather than headaches in general, but does not indicate whether pain other than headache (which also is common following blast exposure) was assessed. If not, it would be hard to attribute physical health effects mostly to PTSD or depression. | This study assessed patients for a number of somatic symptoms in addition to pain. We have changed the wording regarding the findings of this study. It is not possible to say conclusively how PTSD and depression are associated with pain. We now more carefully state, “the associations among TBI and physical health problems are no longer significant when PTSD and depression are included in models.”
Sayer | It is difficult to evaluate the active research for the obvious reason that there are no publications or other products other than the objectives of the study, which are always lofty. The review of active research may give the impression that all gaps will be filled in the near future. I am not sure of that. In many of these studies pain is a secondary outcome and the quality of pain data will be limited. I suggest that you include in Table 2 an indicator of whether the pain outcome is primary/secondary and in your review that you discuss potential limitations associated with many of these active studies (particularly in the limitation section). For example, at least one of the studies is a QI project (Kerns PI). This study will help improve practice, I believe, but I am not sure that it will address KQ1&5 in a generalizeable way. I also think it may be helpful to have the grant #s listed in the reference section as there may be some errors. | We have added a column to Table 2 indicating whether pain-related outcomes are a primary or secondary focus of each study. We will also address these important concerns in a separate limitations section included within the active research section. We will include grant numbers and agencies when available.
Schreiber | No, The review is extremely comprehensive with broad representation of literature from all sectors. There is no evidence of bias. | Noted
Walker, RL | No, the reviewers appeared to provide a balanced review of the evidence that is available at this time. | Noted
Kerns | No; except with regard to the identification of active research projects as described above. | Noted
Question 3. Are there any studies on pain in patients with polytrauma that we have overlooked?
Bair | not, that I know about | Noted
Buffum | Not that I know of. Very comprehensively addressed. | Noted
Clark | None that I know of. | Noted
Schreiber | There is a prospective cohort study on outcome after amputation: Bosse et al, NEJM. 2002;347:1924–1931. This article may have been excluded because it does not mention polytrauma or because it focuses on surgical technique. However, this article is prospective and it give 2 year outcome data in a large amputation population (569 patients). Failure to include articles like this would seem to be a weakness of this review. | We reviewed the suggested study at the full-text level and were not able to include it in our review because pain was not an outcome.
Walker, RL | Not that I am aware of in the current published or non-published literature | Noted
Kerns | None of which I am aware | Noted
Question 4. Future research recommendations table, by key question
KQ1. Are pain assessment tools reliable and valid in patients with cognitive deficits due to TBI?
Buffum | Partnership with family to identify pain behaviors and responses rial of protocol specific to identified pain behaviors such as that used in dementia (Serial Trials Intevention---Kovach et al)--- Include in a tool items found helpful in dementia: combinations (observation, self-report, family report, combination, empiric analgesic, all of these; function, intensity, triggering situations, co-morbidities –both physical and psychological) Qualitative study to identify pain behaviors in different cognitively impaired TBI states. Develop a new tool (match severity and type of cognitive impairment) Evaluate use of the dementia tools in TBI What other tools provide some utility?(unconscious patients in ICU?infants?) | Noted, and included
Clark | Highly needed, but all research in this area suffers from the same problem: What do you use as a criterion when assessing measure validity when patients cannot provide self-reports? Observational studies are the hallmark but generally cannot distinguish between pain-related or dementia/TBI-related behaviors such as agitation, restlessness, etc | Noted
Sayer | Table 4. Why are you recommending qualitative studies to address KQ1? | Qualitative studies often generate hypotheses for subsequent quantitative testing. For example as noted by another reviewer, a qualitative study for Key Question 1 examining pain behaviors/responses identified by family members might lead to development of a new tool for assessing pain in TBI patients.
Schreiber | Develop an assessment tool that differentiates symptoms of TBI from PTSD. Some degree of TBI screening is being performed on injured soldiers being admitted to Landstuhl Regional Medical Center | Noted. We are focusing in this set of research recommendations on evaluation of measures for pain. We will include a research topic on assessing discriminant validity of pain assessment tools.
Kerns | Studies of pain assessment during coma emergence may be an interesting paradigm in which to study the reliability and validity of these assessment tools. Examination of moderators of reliability of the tools including examination of TBI/cognitive dysfunction severity should be encouraged. A key question is the discriminant validity of these assessment tools for distinguishing pain and forms of emotional distress. This should be explicitly stated as an important area for research. A specific strategy for assessment of the validity of these tools is to employ them in the context of clinical trials of pain interventions. That is, evidence for the validity of the measure can come from evidence of declining “pain ratings” in conjunction with delivery of opioid analgesics, for example. As a follow-up to the qualitative study in the PRCs, explicit examination of the reliability, validity, and utility of the module for the assessment of pain among non-communicative patients is indicated. | Noted and included
KQ2a. Which treatments improve pain outcomes in polytrauma patients?
Clark | Trials of telephone-based interventions? | Noted and included
Kerns | Of particular relevance are studies of opioids, since these medications are likely to be used with considerable frequency, are presumed to be associated with increased cognitive dysfunction that may undermine rehabilitation efforts, and are associated with safety risks including respiratory depression, abuse and addiction, and diversion. However, studies of the efficacy of nonpharmacological interventions, especially psychological interventions, are indicated. It seems that virtually any prospective randomized controlled trial in this area is indicated. Systematic prospective observational studies and single case experimental designs with replication may be more likely given the heterogeneity of the population and the relatively small numbers of persons who could be enrolled at one or even a few sites. | Noted and included
KQ2b. Which pain treatment approaches enhance overall rehabilitation efforts?
Clark | RCTs examining a range of treatment approaches including comprehensive interdisciplinary rehab. Additionally, comparisons of Tx for specific conditions (e.g., TBI; PTSD; Pain) could be compared to more general treatment of the core of overlapping symptoms that characterize this polytrauma triad of symptoms (e.g., the “P3” Tx model developed at Tampa). Comparisons of standard vs. low Tx intensity impact. | Noted and included
Kerns | The relationship between improved pain control and rehabilitation outcomes is an important target. Again, systematic prospective observation methods and single case experimental designs with replication are likely to be most useful in this regard. | Noted and included
KQ3a. Does blast-related headache pain differ from other types of headache pain?
Buffum | Impact of comorbid psych issues on headache in these patients (e.g., PTSD or schizophrenia with auditory hallucinations)--- | Noted and included
Clark | Obviously, prospective studies are difficult here unless one follows a large number of deployed soldiers pre and post. More practical would be comparisons of Sx between those with “migraine- like” or “tension-like” post-traumatic headaches and non-posttraumatic migraine and tension HAs, or between those with blast and non-blast post-traumatic HAs | Noted and included
Schreiber | Perform routine imaging on soldiers exposed to blast to assess for structural abnormalities and correlate with headache symptoms | Noted and included
Kerns | A carefully designed cross-sectional study of veterans with either headache presumed to be related to blast-injury or with headache not known to be associated with blast would likely be important and have a high impact. | Noted and included
KQ3b. Which treatments are best for persistent blast-related headache pain?
Clark | Typical HA meds do not seem to be as effective with this cohort according to treating clinicians. Therefore, trials of new meds (or new applications of meds), as well as additive or subtractive studies of meds +− CBT would be useful. | Noted and included
Schreiber | Prospective randomized trials using different pain strategies in patients with blast-related headache pain | Noted and included
Kerns | An RCT of psychological interventions for blast-related headache is feasible and strongly indicated given evidence for the efficacy of similar interventions in other headache populations. Interventions including hypnosis, relaxation training, biofeedback, and cognitive-behavior therapy are particularly indicated. | Noted and included
KQ4a. What patient factors are associated with better and worse (pain-related) clinical outcomes among polytrauma patients?
Clark | 1. Validate value of typical pain outcomes predictors (e.g., depression; catastrophizing; fear; etc.) in this cohort.; 2. Comparisons of pain course between polytrauma and non-polytrauma patients matched by pain type/location; 3. Associations between pain and PTSD and pain and TBI. | Noted and included
Buffum | Partnership with family? | Noted and included
Schreiber | Develop a comprehensive survey tool given to soldiers prior to deployment that includes questions concerning prior injuries, history of pain related issues, medication history, etc. Couple this with the post-deployment assessments at the time of re-deployment and 6 months later. | Noted and included
KQ4b. Have interventions been developed to specifically address these factors?
Clark | Identify factors first. | Noted and included
Kerns | An RCT of psychological interventions for blast-related headache is feasible and strongly indicated given evidence for the efficacy of similar interventions in other headache populations. Interventions including hypnosis, relaxation training, biofeedback, and cognitive-behavior therapy are particularly indicated. | Noted and included
KQ5a. What are unique provider and system barriers to detecting and treating pain among polytrauma patients?
Have interventions been developed to effectively address these barriers?
Buffum | What is the role for nonpharmacologic measures? (hypnosis, acupuncture, massage, music, exercise)--- What cultural adaptations(or acceptance of diversity) are the PRCs doing to accomodate patients with pain? (e.g. cultural or religious practices) | Noted and included
Clark | 1. Impact of polytrauma pain education on provider behavior.; 2. Establishment and subsequent testing of expert opinion Tx guidelines.; 3. Evaluations of patient perceived barriers and impact of efforts to mitigate those barriers. | Noted and included
Kerns | Follow-up of the qualitative study in the PRCs will be important to further examine implementation of CPRS tools for pain assessment. A specific focus on overcoming physician barriers to the conduct of pain assessments in this, and other populations, will be important. Further refinement of the tools to improve provider/nursing use and satisfaction with the tools is likely indicated. | Noted and included
Sayer | For KQ5 I suggest organizational research. | Noted and included
Question 5a (review form). Additional Suggestions for future research
Bair | Informed by this excellent review, I think it would be helpful to hold a consensus meeting(s) based on the IMMPACT group (Initiative on Methods, Measurement, and Pain Assessment in Clinical Trials) to develop consensus recommendations and priorities to populate the table and provide future research recommendations. | We compiled a list of reviewers’ recommendations for specific studies, and sent this list to the expert panel to help prioritize. Because these are preliminary rankings, a panel or other mechanism to achieve consensus is needed to refine and finalize the recommendations for future research.
Buffum | My suggestions are in double columns for Question 1. Wherever partnership with family could be studied as an intervention, I’d suggest that for future research. The role of distraction, nonpharmacologic methods, elements of rehab that are most successful for these pts with multiple injuries including neurological and psychological trauma | Noted and included
Clark | As we knew from the outset, there is little direct research in the general area of polytrauma pain despite the fact that multiple traumas of one type or another have occurred for centuries. Typically trauma medicine is more concerned with survival than pain, rightly so to a degree. But acute-phase pain interventions may offer the most long term benefit for patients in terms of prevention of chronic pain or minimization of its associated disabilities. So one area of valuable research clearly involves this relatively unknown acute phase. Mac’s study tries to address this from one perspective, but a variety of other areas are ripe for exploration as well (eventual impact of improved pain care on or near the battlefield; associations between acute injury pain and injury related emotional issues; etc.). (CONTINUED NEXT ROW) | Noted and included. We have added additional statements regarding the advisability of improving VA-DoD collaborations in our research recommendations section.
Clark (Continued) | The challenge is that almost all of these studies would need to involve BOTH the DoD and VA, and despite occasional reports to the contrary, we have far from a close working relationship between the two. So another priority for me would be to try to foster DoD/VA linkage in the area of pain care similar to initial linkages that have been made in other OEF/OIF care issues (e.g., ID; vascular; surgery; psychiatry). Though not related specifically to research, perhaps a joint DoD/VA working conference or joint work group focusing on identifying ways to collaborate more effectively in pain research would be helpful. Right now, some of us attend some of the annual military medical conferences, but pain rarely is attended to in any detail. Just a thought. | See above.
Schreiber | 1. There is an enormous amount of information that is already available that could be mined for future research. All soldiers returning from deployment undergo a post-deployment assessment questionnaire just prior to leaving the field and 6 months later. Although, the questions are limited, they may provide important insight into later outcomes. These questionnaires could also be modified to make them more useful. 2. Most soldiers undergo pre and post-deployment hearing tests. Soldiers who are not exposed to blast injury could serve as controls for those who are to determine if all of the hearing loss is related to blast injury. For example, my hearing worsened after my deployment and I was not exposed to blast injury. (CONTINUED NEXT ROW) | We have incorporated these ideas into our research recommendation section.
Schreiber (continued) | Additional screening should be routinely performed on soldiers admitted to Landsthuhl Regional Medical Center. All injured soldiers from Iraq and Afghanistan go through LRMC and as a Level 4 facility this is a tremendous opportunity to collect data. 4. It is my understanding that all deploying soldiers have a blood sample taken and stored prior to deployment. This provides an incredible opportunity to study genetic factors associated with chronic pain, PTSD and outcome after TBI. This could result in opportunities for intervention | See above.
Question 5b (review form). Additional comments
Bair | Thank you for highlighting our ESCAPE study in the review. The only suggestion that I have is to include that the comparator is “treatment as usual” or “usual care.” | Correction made.
Bair | 1. Page V (executive summary), Line 37: Suggest adding “ICU” to length of stay to improve clarity | Correction made.
Bair | 2. Page 1, Line 45: Minor typo. Suggest changing first word from On to Among | Correction made.
Bair | 3. Page 2, Line 23: add undiscovered shrapnel fragments | Correction made.
Bair | 4. Page 4–I like the analytic framework diagram. Suggest a minor edit to include a legend noting that KQ = Key Question | Correction made.
Bair | 5. Page 7: Capitalize GRADE (The Grading of Recommendations, Assessment, Development, and Evaluation (GRADE) Working Group–suggest also to write out the acronym | Correction made.
Bair | 6. Page 9–I like the diagram, but a one-word descriptor of each KQ may help the reader. For example under KQ1 you might include Assessment | Correction made.
Bair | 7. Page 12 (lines 28 to 32). Why was no p-value reported for the greater HRQL outcome? In addition, I think the remaining discussion is slightly misleading. The p-values for “increased likelihood to return to work” and “reduced hours of work” were not statistically significant. It may be more accurate to say there was a “trend” towards statistical significance for these outcomes. This should also be changed in the conclusion table. | We have revised the sentence to read as follows: After controlling for demographic factors, injury characteristics and other medical morbidity, inpatient rehabilitation was marginally associated with increased likelihood of return to work (p=0.09) and decreased likelihood of reduced hours of work (p=0.05).
Bair | 8. Pages 13 and 14, Table 1: Is the outcome “global improvement” a patient self-reported or clinician reported outcome? | We have confirmed the global improvement outcome was clinician-reported in this study and have indicated this on Table 1.
Bair | 9. Page 14, Lines 39 and 40: There is some redundancy here (e.g. “in the review” is mentioned twice). | Correction made.
Bair | 10. Page 17, Line 24: Add “ICU” length of stay | Correction made.
Bair | 11. Style point: I might consider more liberal use of bulleted text, especially when describing several studies | Noted.
Bair | 12. Page 21, Lines 28 to 30: Not sure how to edit, but the current wording is awkward | Correction made.
Bair | 13. Page 21, Lines 32 to 34: Suggest edit to say something like “multiply and singly injured patients to reduce redundancy | Correction made.
Bair | 14. Page 23, Line 31: Edit percentages reported–e.g., 44% to 54% and (line 34) 17% to 18% | Correction made.
Bair | 15. Page 23, Line 41: Pain scores are reported but not sure what is the range of scores here? 0 to 100 scale? | The suggested has been added.
Bair | 16. Page 23, line 42: Suggest using the term prevalence instead of “frequency.” | Correction made.
Bair | 17. Page 32, table 3: I like the summary table. It is clear and concise. However, the results of 2b are not all statistically significant and thus may be misleading | We have changed the wording in Table 3 to be more consistent with the findings.
Buffum | Here are some details I noticed as I read: Pg iv line 4 this appears to contradict pg 5 line 46 ? | Pg iv line 4: We systematically rated the quality of cohort and case-control design studies. pg 5 lines 43–46: Due to a limited number of studies that included a comparator group, we also considered relevant cross-sectional and case report/case series studies for inclusion for some of the key questions. For these study designs, data were not formally abstracted nor rated for quality of evidence. Response: The former sentence refers to case- control studies which include a comparator group, whereas the latter refers to case reports/case series that do not include a comparator group.
Buffum | Pg 12 line 30 p value for QOL? | The result has been clarified.
Buffum | Pg 12 #36 and #52 what is complex regional pain syndrome 1? In text it is always 2. | Complex Regional Pain Syndrome 1 is the syndrome previosly known as regional sympathetic dystrophy. Complex Regional Pain Syndrome was previously known as causalgia. We have referred to these older labels when first introducing these syndromes.
Buffum | Pg 19 line 22 headache “density” (should it be “intensity”?) Lines 30–34 inconsistency of p value and r. | Density is the term used by the study author (Walker 2005). We have defined his usage of the density in the text. The p-value in line 31 and the r-value in line 35 refer to the results of separate studies.
Buffum | Pg 22 line 30 to summarize, there “are”…. (should it be “is”?) | Correction made.
Buffum | Pg 26 2nd to last row on the bottom (127) in 2nd column: Compare cost costs. (delete “cost”) | Correction made.
Buffum | Pg 31 line 7 Two librarians independently search…. (should be “searched”?) | Correction made.
Buffum | Pg 32 Key Question 1 second bullet….Most patients with mild cognitive impairment … (add “mild”) Add a bullet: There is no evidence that pain assessment tools for dementia could be reliably applied to persons with cognitive impairment related to TBI. | Correction made.
Helmer | I was a little taken aback by your summary of the Hoge TBI paper (ref 54) on page 15. “overall, the analyses suggest that…high rates of physical health problems…are mediated largely by PTSD and depression.” “Mediated” doesn’t necessarily imply causality, of course, but I think you need to be a little more careful about stating it in such a way to not be interpreted as “PTSD and depression explain the high rates of physical health problems.” How about the associations between TBI and physical health problems were no longer significant after inclusion of PTSD and depression? | We agree and have corrected the error.

Reviewers

Bair | Matthew J. Bair, MD, MS
Buffum | Martha Buffum, DNSC, APRN, BC, CS
Clark | Michael E. Clark, Ph.D.
Helmer | Drew Helmer, M.D.
Kerns | Robert Kerns, Ph.D.
Otis | John D. Otis, Ph.D.
Sayer | Nina Sayer, Ph.D.
Schreiber | Martin A. Schreiber, MD
Walker, RL | Robyn L. Walker, Ph.D.