# ARTICLE SCREENING FORM

Article Screening Form