# SEARCH STRATEGY

Two librarians (AH and RC) independently designed search strategies based on the key questions. The results of both searches were combined into a single reference library.

Below is the search strategy designed by AH:
Database: Ovid MEDLINE(R) <1950 to January Week 5 2008> Search Strategy:
1 | polytraum$.mp. (2115)
2 | exp Multiple Trauma/(7404)
3 | (multiple adj3 (wound$ or injur$ or traum$ or casualt$)).mp. (12171)
4 | 1 or 2 or 3 (13048)
5 | exp Blast Injuries/(1862)
6 | exp Brain Injuries/(34104)
7 | ((head or crani$ or cereb$ or brain$ or explosi$ or explod$ or blast$) adj3 (traum$ or wound$ or injur$ or damag$)).mp. (88531)
8 | 5 or 6 or 7 (90818)
9 | exp pain/(218224)
10 | exp pain measurement/(33373)
11 | exp nociceptors/(8377)
12 | (pain$ or agony or agoniz$ or nocicept$).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (334241)
13 | 9 or 10 or 11 or 12 (392032)
14 | 9 or 10 (230078)
15 | 4 and 14 (175)
16 | 5 and 14 (12)
17 | exp War/(25443)
18 | exp Military Personnel/(15657)
19 | exp Military Medicine/(21662)
20 | exp Veterans/(5122)
21 | exp Veterans Disability Claims/(209)
22 | Hospitals, Veterans/(4480)
23 | exp “United States Department of Veterans Affairs”/(3021)
24 | (desert storm or gulf war or enduring freedom or iraqi freedom).mp. (1606) 25exp Iraq War, 2003 -/or exp Iraq/(2569)
26 | (iraq or soldier$ or veteran$ or combat$ or militar$ or battle$).mp. (77729)
27 | 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 (94873)
28 | exp “wounds and injuries”/or in.fs. (580168)
29 | 27 and 28 (9834)
30 | 8 and 13 (1988)
31 | limit 30 to humans (1836)
32 | limit 31 to english language (1402)
33 | limit 31 to abstracts (1447)
34 | 32 or 33 (1681)
35 | 4 and 13 (500)
36 | limit 35 to humans (491)
37 | limit 36 to english language (359)
38 | limit 36 to abstracts (465)
39 | 37 or 38 (483)
40 | 13 and 29 (449)
41 | limit 40 to humans (441)
42 | limit 41 to english language (383)
43 | limit 41 to abstracts (375)
44 | 42 or 43 (424)
45 | 34 or 39 or 44 (2480)
46 | limit 45 to yr=“2000 – 2008” (1163)
47 | limit 45 to yr=“1902 – 1999” (1317)
48 | from 47 keep 1 (1)

Below is the search strategy designed by RC. This search was saved in PubMed to provide automatic weekly updates:

“Brain Injuries”(142)

OR “Multiple Trauma”(142)

OR “Blast Injuries”(142)

OR TBI[All Fields]

OR “traumatic brain injury”[All Fields]

OR “traumatic brain injuries”[All Fields]

OR polytrauma[All Fields]

OR multitrauma[All Fields]

OR “multi trauma”[All Fields]

OR “poly trauma”[All Fields]

OR ((“Wounds and Injuries”(142) OR “injuries “[Subheading]) AND (“War”(142) OR “Iraq War, 2003 -”(142)

OR “Gulf War”(142)))

AND (“pain”[MeSH Terms] OR pain[Text Word])